# Publications That Did Not Provide Specific Results for Stage II Colon Cancer

1 Ägesen TH, Sveen A, Merok MA, et al. ColoGuideEx: a robust gene classifier specific for stage II colorectal cancer prognosis. Gut. 2012. Jan. 2. [pmid: 22213796].
2 Antonacopoulou AG, Grivas PD, Skarlas L, et al. POLR2F, ATP6V0A1 and PRNP expression in colorectal cancer: new molecules with prognostic significance?. Anticancer Research. Mar–Apr. 2008;28(2B):1221-7. [pmid: 18505059].
3 Barrier A, Boelle P-Y, Lemoine A, et al. Gene expression profiling of nonneoplastic mucosa may predict clinical outcome of colon cancer patients. Diseases of the Colon & Rectum. Dec. 2005;48(12):2238-48. [pmid: 16228831].
4 Barrier A, Lemoine A, Boelle P-Y, et al. Colon cancer prognosis prediction by gene expression profiling. Oncogene. Sep. 8. 2005;24(40):6155-64. [pmid: 16091735].
5 Camus M, Tosolini M, Mlecnik B, et al. Coordination of intratumoral immune reaction and human colorectal cancer recurrence. Cancer Research. Mar. 15. 2009;69(6):2685-93. [pmid: 19258510].
6 Coppola D, Nebozhyn M, Khalil F, et al. Unique ectopic lymph node-like structures present in human primary colorectal carcinoma are identified by immune gene array profiling. American Journal of Pathology. Jul. 2011;179(1):37-45. [pmid: 21703392].
7 Deves C, Renck D, Garicochea B, et al. Analysis of select members of the E26 (ETS) transcription factors family in colorectal cancer. Virchows Archiv. Apr. 2011;458(4):421-30. [pmid: 21318373].
8 Fritzmann J, Morkel M, Besser D, et al. A colorectal cancer expression profile that includes transforming growth factor beta inhibitor BAMBI predicts metastatic potential. Gastroenterology. Jul. 2009;137(1):165-75. [pmid: 19328798].
9 Gröene J, Mansmann U, Meister R, et al. Transcriptional census of 36 microdissected colorectal cancers yields a gene signature to distinguish UICC II and III. [Erratum appears in Int J Cancer. 2007 Jul 15;121(2):466]. International Journal of Cancer. Oct. 15. 2006;119(8):1829-36. [pmid: 16721809].
10 Jorissen RN, Gibbs P, Christie M, et al. Metastasis-Associated Gene Expression Changes Predict Poor Outcomes in Patients with Dukes Stage B and C Colorectal Cancer. Clin Cancer Res. Dec. 15. 2009;15(24):7642-51. [pmid: 19996206].
11 Kammula US, Kuntz EJ, Francone TD, et al. Molecular co-expression of the c-Met oncogene and hepatocyte growth factor in primary colon cancer predicts tumor stage and clinical outcome. Cancer Letters. Apr. 18. 2007;248(2):219-28. [pmid: 16945480].
12 Kornmann M, Schwabe W, Sander S, et al. Thymidylate synthase and dihydropyrimidine dehydrogenase mRNA expression levels: predictors for survival in colorectal cancer patients receiving adjuvant 5-fluorouracil. Clinical Cancer Research. Sep. 15. 2003;9(11):4116-24. [pmid: 14519634].
13 Loboda A, Nebozhyn MV, Watters JW, et al. EMT is the dominant program in human colon cancer. BMC Medical Genomics. [Electronic Resource]. 2011;4:9. [pmid: 21251323].
14 Lassmann S, Hennig M, Rosenberg R, et al. Thymidine phosphorylase, dihydropyrimidine dehydrogenase and thymidylate synthase mRNA expression in primary colorectal tumors-correlation to tumor histopathology and clinical follow-up. International Journal of Colorectal Disease. Apr. 2006;21(3):238-47. [pmid: 16132996].
15 Lenehan PF, Boardman LA, Riegert-Johnson D, et al. Generation and external validation of a tumor-derived 5-gene prognostic signature for recurrence of lymph node-negative, invasive colorectal carcinoma. Cancer. 2012. May. 17. [pmid: 22605513].
16 Lin Y-H, Friederichs J, Black MA, et al. Multiple gene expression classifiers from different array platforms predict poor prognosis of colorectal cancer. Clinical Cancer Research. Jan. 15. 2007;13(2 Pt 1):498-507. [pmid: 17255271].
17 Merlos-Suarez A, Barriga FM, Jung P, et al. The intestinal stem cell signature identifies colorectal cancer stem cells and predicts disease relapse. Cell Stem Cell. May. 6. 2011;8(5):511-24. [pmid: 21419747].
18 Nitsche U, Maak M, Schuster T, et al. ColoPrint® – ein vielversprechender Gentest zur Risikoabschätzung bei Patienten mit Kolonkarzinom. Journal Onkologie. 2012:454-6. (english language abstract).
19 Popovici V, Budinska E, Tejpar S, et al. Identification of a poor-prognosis BRAF-mutant-like population of patients with colon cancer. J Clin Oncol. Apr. 20. 2012;30(12):1288-95. [pmid: 22393095].
20 Pogue-Geile KL, Yothers GA, Gavin P, et al. Use of a prognostic (prog) gene index and nodal status to identify a subset of stage II and III colon cancer patients (pts) who may not need oxaliplatin (ox)-containing adjuvant chemotherapy. Journal of Clinical Oncology Conference. 2010;28(15 SUPPL 1).
21 Staub E, Groene J, Heinze M, et al. An expression module of WIPF1-coexpressed genes identifies patients with favorable prognosis in three tumor types. Journal of Molecular Medicine. Jun. 2009;87(6):633-44. [pmid: 19399471].
22 Vendrell E, Ribas M, Valls J, et al. Genomic and transcriptomic prognostic factors in R0 Dukes B and C colorectal cancer patients. International Journal of Oncology. May. 2007;30(5):1099-107. [pmid: 17390011].
23 Yamasaki M, Takemasa I, Komori T, et al. The gene expression profile represents the molecular nature of liver metastasis in colorectal cancer. International Journal of Oncology. Jan. 2007;30(1):129-38. [pmid: 17143521].