# Elements Abstracted From Included Articles

For all articles:

- Article (details regarding author(s), institutions, funding)
- Which test(s) were used?
  ○ Type(s) of tissue used (e.g., fresh tissue)
  ○ Time for analysis (turnaround time)
- Inclusion and exclusion criteria
  ○ Was only a subset of patients with stage II disease used? If so, which one?
  ○ For adjuvant chemotherapy, which regimens were used?
    ■ Sample size (number of patients/specimens)
  ○ If samples are from previous studies, which studies?
    ■ Is there information to assess the completeness of sampling from previous studies?

For articles that describe analytic validity:

- Was information provided about preanalytic factors (e.g., handling of specimens)?
- What aspects of analytic validity were measured (e.g., accuracy, reproducibility)?
- Does it provide narrative summary of results related to analytic validity?

For articles that describe clinical validity and clinical utility:

- What outcomes were measured, for example, recurrence rates, response to adjuvant chemotherapy (regimen specific), avoidance of chemotherapy (with reduction in medication side effects), et cetera?
- What was the study design?
  ○ Prospective, retrospective, or prospective-retrospective
  ○ Randomized trial, controlled trial, cohort study, or case (convenience) series
  ○ Derivation and/or validation (For validation, when was the method of analysis and interpretation determined?)
- Was a reclassification analysis performed (to determine if the GEP test results provide new (additional) information when compared with that obtained with usual predictors)?
- Was MSI (MMR) status determined?
  ○ If so, by which method?
- Was MSI (MMR) status considered in the overall analysis?
  ○ If so, how?
- Was the GEP performed (analysis, calculation, interpretation) as described in initial studies for derivation and/or studies of analytic validity?
- Does the final classification provide discrimination among groups of patients; that is, are the patients grouped into a specific category that is distinct and different from other categories? (In addition, when the GEP predicts risk groups, how were the cut-points for various groups determined?)
- Do the authors comment on factors such as race and ethnic background that could impact the generalizability of the findings?
- For blinding, were determinations of the outcomes and the GEP result made independently, that is, did those assessing outcomes know the results of GEP testing?

The following additional information will be obtained from these articles (related to the validity of the outcomes):

○ For recurrence of disease, how was it measured (duration of followup, biopsy result, imaging finding, level of carcinoembryonic antigen, etc.)?
○ For response to adjuvant chemotherapy, how was it measured?
○ For disease-free survival, how was it determined?

Note: Study results will NOT be abstracted.