# Search Strategy for MEDLINE^®^

1. exp Colorectal Neoplasms/
2. ((colorectal or colon$ or rectal or Sigmoid) adj3 (neoplasm$ or cancer$ or carcino$ or tumo?r$)).tw.
3. 1 or 2
4. Gene Expression Profiling/
5. (gene expression adj (profil$ or monitor$ or pattern$ or signature$ or predictor$ or test$ or chip$ or regulation)).tw.
6. transcript$ expression analys$.tw.
7. transcriptom$.tw.
8. ((DNA or cDNA or tissue) adj (fingerprint$ or microarray$)).tw.
9. ((mrna or mirna or Microarray or MicroRNA) adj2 (profil$ or expression or signature$)).tw.
10. array sequence analysis.tw.
11. oncotype dx.tw.
12. Affymetrix.tw.
13. Coloprint.tw.
14. (Mismatch repair deficiency status or dmmr).tw.
15. microsatellite instability/
16. Microsatellite Repeats/
17. replication error phenotype$.tw.
18. or/4–17
19. recurrence/
20. (recur$ or relaps$).tw.
21. exp treatment outcome/
22. (respons$ or outcome$ or react$ or eligibl$).tw.
23. Chemotherapy, Adjuvant/
24. (adjuvant or chemotherap$).tw.
25. or/19–24
26. incidence/
27. exp mortality/
28. follow up studies/
29. prognos$.tw.
30. predict$.tw.
31. course$.tw.
32. or/26–31
33. and/3,18,25,32
34. (animals not humans).sh.
35. 33 not 34