# Acknowledgments

The authors gratefully acknowledge the thoughtful input of our Clinical Content Expert, Mohamedtaki A. Tejani, M.D., University of Rochester Medical Center, as well as our Key Informants for their helpful discussion and insights. We could also like to thank the following individuals for their contributions to this project: Claudia Bonnell, R.N., M.L.S.; Ryan Chopra, M.P.H.; Lisa Garofalo, B.A.; Lisa Sarsany, M.A.; and Kathleen M. Ziegler, Pharm.D.