# References

1 Burrow TA, Hopkin RJ, Leslie ND, et al. Enzyme reconstitution/replacement therapy for lysosomal storage diseases. Curr Opin Pediatr. Dec. 2007;19(6):628-35. [pmid: 18025928].
2 Heese BA. Current strategies in the management of lysosomal storage diseases. Semin Pediatr Neurol. Sep. 2008;15(3):119-26. [pmid: 18708002].
3 Staretz-Chacham O, Lang TC, LaMarca ME, et al. Lysosomal storage disorders in the newborn. Pediatrics. Apr. 2009;123(4):1191-207. [pmid: 19336380].
4 Wang RY, Bodamer OA, Watson MS, et al. Lysosomal storage diseases: diagnostic confirmation and management of presymptomatic individuals. Genet Med. May. 2011;13(5):457-84. [pmid: 21502868].
5 Meikle PJ, Hopwood JJ, Clague AE, et al. Prevalence of lysosomal storage disorders. JAMA. Jan. 20. 1999;281(3):249-54. [pmid: 9918480].
6 Wilcox WR. Lysosomal storage disorders: the need for better pediatric recognition and comprehensive care. J Pediatr. May. 2004;144(5 Suppl):S3-14. [pmid: 15126978].
7 Beck M. Emerging drugs for lysosomal storage diseases. Expert Opin Emerg Drugs. Sep. 2010;15(3):495-507. [pmid: 20557271].
8 Bruni S, Loschi L, Incerti C, et al. Update on treatment of lysosomal storage diseases. Acta Myol. Jul. 2007;26(1):87-92. [pmid: 17915580].
9 Beck M. New therapeutic options for lysosomal storage disorders: enzyme replacement, small molecules and gene therapy. Hum Genet. Mar. 2007;121(1):1-22. [pmid: 17089160].
10 Connock M, Burls A, Frew E, et al. The clinical effectiveness and cost-effectiveness of enzyme replacement therapy for Gaucher’s disease: a systematic review. Health Technol Assess. Jul. 2006;10(24):iii-iv. ix. 136. [pmid: 16796930].
11 Connock M, Juarez-Garcia A, Frew E, et al. A systematic review of the clinical effectiveness and cost-effectiveness of enzyme replacement therapies for Fabry’s disease and mucopolysaccharidosis type 1. Health Technol Assess. Jun. 2006;10(20):iii-iv. ix. 113. [pmid: 16729919].
12 Brady RO. Enzyme replacement for lysosomal diseases. Annu Rev Med. 2006;57:283-96. [pmid: 16409150].
13 Brady RO, Schiffmann R. Enzyme-replacement therapy for metabolic storage disorders. Lancet Neurol. Dec. 2004;3(12):752-6. [pmid: 15556808].
14 Hollak CE. An evidence-based review of the potential benefits of taliglucerase alfa in the treatment of patients with Gaucher disease. Core Evid. 2012;7:15-20. [pmid: 22654679].
15 Grubb JH, Vogler C, Sly WS. New strategies for enzyme replacement therapy for lysosomal storage diseases. Rejuvenation Res. Apr–Jun. 2010;13(2–3):229-36. [pmid: 20345279].
16 Beck M. Therapy for lysosomal storage disorders. IUBMB Life. Jan. 2010;62(1):33-40. [pmid: 20014233].
17 Grabowski GA. Gaucher’s disease. Enzyme therapy is not enough. Lancet. Dec. 2001;358(Suppl):S29. [pmid: 11784578].
18 Butters TD, Dwek RA, Platt FM. New therapeutics for the treatment of glycosphingolipid lysosomal storage diseases. Adv Exp Med Biol. 2003;535:219-26. [pmid: 14714898].
19 Butters TD, Dwek RA, Platt FM. Therapeutic applications of imino sugars in lysosomal storage disorders. Curr Top Med Chem. 2003;3(5):561-74. [pmid: 12570866].
20 Butters TD, Dwek RA, Platt FM. Imino sugar inhibitors for treating the lysosomal glycosphingolipidoses. Glycobiology. Oct. 2005;15(10):43R-52R. [pmid: 15329358].
21 Butters TD, Mellor HR, Narita K, et al. Small-molecule therapeutics for the treatment of glycolipid lysosomal storage disorders. Philos Trans R Soc Lond B Biol Sci. May. 29. 2003;358(1433):927-45. [pmid: 12803927].
22 Cox TM, Aerts JM, Andria G, et al. The role of the iminosugar N-butyldeoxynojirimycin (miglustat) in the management of type I (non-neuronopathic) Gaucher disease: a position statement. J Inherit Metab Dis. 2003;26(6):513-26. [pmid: 14605497].
23 Jeyakumar M, Dwek RA, Butters TD, et al. Storage solutions: treating lysosomal disorders of the brain. Nat Rev Neurosci. Sep. 2005;6(9):713-25. [pmid: 16049428].
24 Lachmann RH. Miglustat: substrate reduction therapy for glycosphingolipid lysosomal storage disorders. Drugs Today (Barc). Jan. 2006;42(1):29-38. [pmid: 16511609].
25 Pastores GM, Barnett NL. Substrate reduction therapy: miglustat as a remedy for symptomatic patients with Gaucher disease type 1. Expert Opin Investig Drugs. Feb. 2003;12(2):273-81. [pmid: 12556220].
26 Platt FM, Jeyakumar M. Substrate reduction therapy. Acta Paediatr Suppl. Apr. 2008;97(457):88-93. [pmid: 18339196].
27 Tifft CJ, Proia RL. Stemming the tide: glycosphingolipid synthesis inhibitors as therapy for storage diseases. Glycobiology. Dec. 2000;10(12):1249-58. [pmid: 11159916].
28 Ratko TA, Belinson SE, Brown HM, et al. Hematopoietic Stem-Cell Transplantation in the Pediatric Population. Rockville (MD). 2012.
29 Muenzer J, Wraith JE, Clarke LA. Mucopolysaccharidosis I: Management and treatment guidelines. Pediatrics. 2009;123(1):19-29. [pmid: 19117856].
30 Giugliani R, Harmatz P, Wraith JE. Management guidelines for mucopolysaccharidosis VI. Pediatrics. 2007;120(2):405-18. [pmid: 17671068].
31 Pham B, Klassen TP, Lawson ML, et al. Language of publication restrictions in systematic reviews gave different results depending on whether the intervention was conventional or complementary. J Clin Epidemiol. Aug. 2005;58(8):769-76. [pmid: 16086467].
32 Sidransky E, Pastores GM, Mori M. Dosing enzyme replacement therapy for Gaucher disease: older, but are we wiser?. Genet Med. Feb. 2009;11(2):90-1. [pmid: 19265747].
33 Zimran A, Elstein D, Beutler E. Low-dose therapy trumps high-dose therapy again in the treatment of Gaucher disease. Blood. Aug. 1. 2006;108(3):802-3. [pmid: 16861338].
34 Cohen IJ, Katz K, Kornreich L, et al. Low-dose high-frequency enzyme replacement therapy prevents fractures without complete suppression of painful bone crises in patients with severe juvenile onset type I Gaucher disease. Blood Cells Mol Dis. Sep. 1998;24(3):296-302. [pmid: 10087987].
35 Banikazemi M, Bultas J, Waldek S, et al. Agalsidase-beta therapy for advanced Fabry disease: a randomized trial. Ann Intern Med. Jan. 16. 2007;146(2):77-86. [pmid: 17179052].
36 Germain DP, Waldek S, Banikazemi M, et al. Sustained, long-term renal stabilization after 54 months of agalsidase beta therapy in patients with Fabry disease. J Am Soc Nephrol. May. 2007;18(5):1547-57. [pmid: 17409312].
37 Wraith JE, Tylki-Szymanska A, Guffon N, et al. Safety and efficacy of enzyme replacement therapy with agalsidase beta: an international, open-label study in pediatric patients with Fabry disease. J Pediatr. Apr. 2008;152(4):563-70. 70 e1. [pmid: 18346516].
38 Barton NW, Brady RO, Dambrosia JM, et al. Replacement therapy for inherited enzyme deficiency–macrophage-targeted glucocerebrosidase for Gaucher’s disease. N Engl J Med. May. 23. 1991;324(21):1464-70. [pmid: 2023606].
39 Elstein D, Cohn GM, Wang N, et al. Early achievement and maintenance of the therapeutic goals using velaglucerase alfa in type 1 Gaucher disease. Blood Cells Mol Dis. Jan. 15. 2011;46(1):119-23. [pmid: 20727796].
40 Grabowski GA, Barton NW, Pastores G, et al. Enzyme therapy in type 1 Gaucher disease: comparative efficacy of mannose-terminated glucocerebrosidase from natural and recombinant sources. Ann Intern Med. Jan. 1. 1995;122(1):33-9. [pmid: 7985893].
41 Kishnani PS, DiRocco M, Kaplan P, et al. A randomized trial comparing the efficacy and safety of imiglucerase (Cerezyme) infusions every 4 weeks versus every 2 weeks in the maintenance therapy of adult patients with Gaucher disease type 1. Mol Genet Metab. Apr. 2009;96(4):164-70. [pmid: 19195916].
42 Sims KB, Pastores GM, Weinreb NJ, et al. Improvement of bone disease by imiglucerase (Cerezyme) therapy in patients with skeletal manifestations of type 1 Gaucher disease: results of a 48-month longitudinal cohort study. Clin Genet. May. 2008;73(5):430-40. [pmid: 18312448].
43 Zimran A, Altarescu G, Philips M, et al. Phase 1/2 and extension study of velaglucerase alfa replacement therapy in adults with type 1 Gaucher disease: 48-month experience. Blood. Jun. 10. 2010;115(23):4651-6. [pmid: 20299511].
44 Zimran A, Brill-Almon E, Chertkoff R, et al. Pivotal trial with plant cell-expressed recombinant glucocerebrosidase, taliglucerase alfa, a novel enzyme replacement therapy for Gaucher disease. Blood. Nov. 24. 2011;118(22):5767-73. [pmid: 21900191].
45 Sawkar AR, D’Haeze W, Kelly JW. Therapeutic strategies to ameliorate lysosomal storage disorders–a focus on Gaucher disease. Cell Mol Life Sci. May. 2006;63(10):1179-92. [pmid: 16568247].
46 Desnick RJ. Enzyme replacement and enhancement therapies for lysosomal diseases. J Inherit Metab Dis. 2004;27(3):385-410. [pmid: 15190196].
47 Vedder AC, Breunig F, Donker-Koopman WE, et al. Treatment of Fabry disease with different dosing regimens of agalsidase: effects on antibody formation and GL-3. Mol Genet Metab. Jul. 2008;94(3):319-25. [pmid: 18424138].
48 de Fost M, Aerts JM, Groener JE, et al. Low frequency maintenance therapy with imiglucerase in adult type I Gaucher disease: a prospective randomized controlled trial. Haematologica. Feb. 2007;92(2):215-21. [pmid: 17296571].
49 Giugliani R, Rojas VM, Martins AM, et al. A dose-optimization trial of laronidase (Aldurazyme) in patients with mucopolysaccharidosis I. Mol Genet Metab. Jan. 2009;96(1):13-9. [pmid: 19038563].
50 Muenzer J, Gucsavas-Calikoglu M, McCandless SE, et al. A phase I/II clinical trial of enzyme replacement therapy in mucopolysaccharidosis II (Hunter syndrome). Mol Genet Metab. Mar. 2007;90(3):329-37. [pmid: 17185020].
51 Muenzer J, Wraith JE, Beck M, et al. A phase II/III clinical study of enzyme replacement therapy with idursulfase in mucopolysaccharidosis II (Hunter syndrome). Genet Med. Aug. 2006;8(8):465-73. [pmid: 16912578].
52 Harmatz P, Whitley CB, Waber L, et al. Enzyme replacement therapy in mucopolysaccharidosis VI (Maroteaux-Lamy syndrome). J Pediatr. May. 2004;144(5):574-80. [pmid: 15126989].
53 Harmatz P, Yu ZF, Giugliani R, et al. Enzyme replacement therapy for mucopolysaccharidosis VI: evaluation of long-term pulmonary function in patients treated with recombinant human N-acetylgalactosamine 4-sulfatase. J Inherit Metab Dis. Feb. 2010;33(1):51-60. [pmid: 20140523].
54 Laney DJ, White AL, Rhead WJ, et al. Creating genetics-based infusion centers: a case study of two models. Genet Med. Aug. 2008;10(8):626-32. [pmid: 18641514].
55 Bailey L. An overview of enzyme replacement therapy for lysosomal storage diseases. OJIN: The Online Journal of Issues in Nursing. 2008;13(1). Manuscript 3.
56 Burton BK, Wiesman C, Paras A, et al. Home infusion therapy is safe and enhances compliance in patients with mucopolysaccharidoses. Mol Genet Metab. Jul. 2009;97(3):234-6. [pmid: 19427803].
57 Milligan A, Hughes D, Goodwin S, et al. Intravenous enzyme replacement therapy: better in home or hospital?. Br J Nurs. Mar 23–Apr 12. 2006;15(6):330-3. [pmid: 16628169].
58 Hughes DA, Mlilligan A, Mehta A. Home therapy for lysosomal storage disorders. Br J Nurs. Dec 13–2008 Jan 9. 6. 2007;16(22):1384-9. [pmid: 18361386].
59 Zimran A, Hollak CE, Abrahamov A, et al. Home treatment with intravenous enzyme replacement therapy for Gaucher disease: an international collaborative study of 33 patients. Blood. Aug. 15. 1993;82(4):1107-9. [pmid: 8353277].
60 Linthorst GE, Vedder AC, Ormel EE, et al. Home treatment for Fabry disease: practice guidelines based on 3 years experience in The Netherlands. Nephrol Dial Transplant. Feb. 2006;21(2):355-60. [pmid: 16249196].
61 Cox-Brinkman J, Timmermans RG, Wijburg FA, et al. Home treatment with enzyme replacement therapy for mucopolysaccharidosis type I is feasible and safe. J Inherit Metab Dis. Nov. 2007;30(6):984. [pmid: 17879143].
62 Bagewadi S, Roberts J, Mercer J, et al. Home treatment with Elaprase and Naglazyme is safe in patients with mucopolysaccharidoses types II and VI, respectively. J Inherit Metab Dis. Dec. 2008;31(6):733-7. [pmid: 18923918].
63 Tifft C, Proud V, Levy P, et al. Enzyme replacement therapy in the home setting for mucopolysaccharidosis VI: a survey of patient characteristics and physicians’ early findings in the United States. J Infus Nurs. Jan–Feb. 2009;32(1):45-52. [pmid: 19142150].
64 Cousins A, Lee P, Rorman D, et al. Home-based infusion therapy for patients with Fabry disease. Br J Nurs. May 22–Jun 11. 2008;17(10):653-7. [pmid: 18563007].
65 Burton BK, Guffon N, Roberts J, et al. Home treatment with intravenous enzyme replacement therapy with idursulfase for mucopolysaccharidosis type II - data from the Hunter Outcome Survey. Mol Genet Metab. Oct–Nov. 2010;101(2–3):123-9. [pmid: 20638311].
66 Wraith JE, Beck M, Giugliani R, et al. Initial report from the Hunter Outcome Survey. Genet Med. Jul. 2008;10(7):508-16. [pmid: 18580692].
67 Moher D, Liberati A, Tetzlaff J, et al. Preferred Reporting Items for Systematic Reviews and Meta-Analyses: The PRISMA Statement. PLoS Med. 2009;6(7):e1000097. [pmid: 19621072].
68 Eto Y, Ohashi T, Utsunomiya Y, et al. Enzyme replacement therapy in Japanese Fabry disease patients: the results of a phase 2 bridging study. J Inherit Metab Dis. 2005;28(4):575-83. [pmid: 15902561].
69 Eng CM, Guffon N, Wilcox WR, et al. Safety and efficacy of recombinant human alpha-galactosidase A–replacement therapy in Fabry’s disease. N Engl J Med. Jul. 5. 2001;345(1):9-16. [pmid: 11439963].
70 Vedder AC, Linthorst GE, Houge G, et al. Treatment of Fabry disease: outcome of a comparative trial with agalsidase alfa or beta at a dose of 0.2 mg/kg. PLoS One. 2007;2(7):e598. [pmid: 17622343].
71 Tahir H, Jackson LL, Warnock DG. Antiproteinuric therapy and fabry nephropathy: sustained reduction of proteinuria in patients receiving enzyme replacement therapy with agalsidase-beta. J Am Soc Nephrol. Sep. 2007;18(9):2609-17. [pmid: 17656478].
72 Orlikowski D, Pellegrini N, Prigent H, et al. Recombinant human acid alpha-glucosidase (rhGAA) in adult patients with severe respiratory failure due to Pompe disease. Neuromuscul Disord. Jul. 2011;21(7):477-82. [pmid: 21550241].
73 van der Ploeg AT, Clemens PR, Corzo D, et al. A randomized study of alglucosidase alfa in late-onset Pompe’s disease. N Engl J Med. Apr. 15. 2010;362(15):1396-406. [pmid: 20393176].
74 Strothotte S, Strigl-Pill N, Grunert B, et al. Enzyme replacement therapy with alglucosidase alfa in 44 patients with late-onset glycogen storage disease type 2: 12-month results of an observational clinical trial. J Neurol. Jan. 2010;257(1):91-7. [pmid: 19649685].
75 Kishnani PS, Corzo D, Leslie ND, et al. Early treatment with alglucosidase alpha prolongs long-term survival of infants with Pompe disease. Pediatr Res. Sep. 2009;66(3):329-35. [pmid: 19542901].
76 Kishnani PS, Nicolino M, Voit T, et al. Results from phase II trial of chinese hamster ovary cell-derived recombinant human acid alpha-glucosidase in infantile-onset Pompe disease. J Pediatr. Jul. 2006;149(1):89-97. [pmid: 16860134].
77 Nicolino M, Byrne B, Wraith JE, et al. Clinical outcomes after long-term treatment with alglucosidase alfa in infants and children with advanced Pompe disease. Genet Med. Mar. 2009;11(3):210-9. [pmid: 19287243].
78 Levine JC, Kishnani PS, Chen YT, et al. Cardiac remodeling after enzyme replacement therapy with acid alpha-glucosidase for infants with Pompe disease. Pediatr Cardiol. Nov. 2008;29(6):1033-42. [pmid: 18661169].
79 McDowell R, Li JS, Benjamin DK Jr, et al. Arrhythmias in patients receiving enzyme replacement therapy for infantile Pompe disease. Genet Med. Oct. 2008;10(10):758-62. [pmid: 18813140].
80 Knight AW, Senior TP. The common problem of rare disease in general practice. Med J Aust. Jul. 17. 2006;185(2):82-3. [pmid: 16842062].
81 Jongen SP, Gerwig GJ, Leeflang BR, et al. N-glycans of recombinant human acid alpha-glucosidase expressed in the milk of transgenic rabbits. Glycobiology. Jun. 2007;17(6):600-19. [pmid: 17293352].
82 Clarke LA, Wraith JE, Beck M, et al. Long-term efficacy and safety of laronidase in the treatment of mucopolysaccharidosis I. Pediatrics. Jan. 2009;123(1):229-40. [pmid: 19117887].
83 Wraith JE, Beck M, Lane R, et al. Enzyme replacement therapy in patients who have mucopolysaccharidosis I and are younger than 5 years: results of a multinational study of recombinant human alpha-L-iduronidase (laronidase). Pediatrics. Jul. 2007;120(1):e37-46. [pmid: 17606547].
84 Wraith JE, Clarke LA, Beck M, et al. Enzyme replacement therapy for mucopolysaccharidosis I: a randomized, double-blinded, placebo-controlled, multinational study of recombinant human alpha-L-iduronidase (laronidase). J Pediatr. May. 2004;144(5):581-8. [pmid: 15126990].
85 Kakkis ED, Muenzer J, Tiller GE, et al. Enzyme-replacement therapy in mucopolysaccharidosis I. N Engl J Med. Jan. 18. 2001;344(3):182-8. [pmid: 11172140].
86 Muenzer J, Beck M, Eng CM, et al. Long-term, open-labeled extension study of idursulfase in the treatment of Hunter syndrome. Genet Med. Feb. 2011;13(2):95-101. [pmid: 21150784].
87 Muenzer J, Beck M, Giugliani R, et al. Idursulfase treatment of Hunter syndrome in children younger than 6 years: results from the Hunter Outcome Survey. Genet Med. Feb. 2011;13(2):102-9. [pmid: 21233716].
88 Okuyama T, Tanaka A, Suzuki Y, et al. Japan Elaprase Treatment (JET) study: idursulfase enzyme replacement therapy in adult patients with attenuated Hunter syndrome (Mucopolysaccharidosis II, MPS II). Mol Genet Metab. Jan. 2010;99(1):18-25. [pmid: 19773189].
89 Harmatz P, Ketteridge D, Giugliani R, et al. Direct comparison of measures of endurance, mobility, and joint function during enzyme-replacement therapy of mucopolysaccharidosis VI (Maroteaux-Lamy syndrome): Results after 48 weeks in a phase 2 open-label clinical study of recombinant human N-acetylgalactosamine 4-sulfatase. Pediatrics. 2005;115(6):e681-e9. [pmid: 15930196].
90 Harmatz P, Giugliani R, Schwartz I, et al. Enzyme replacement therapy for mucopolysaccharidosis VI: a phase 3, randomized, double-blind, placebo-controlled, multinational study of recombinant human N-acetylgalactosamine 4-sulfatase (recombinant human arylsulfatase B or rhASB) and follow-on, open-label extension study. J Pediatr. Apr. 2006;148(4):533-9. [pmid: 16647419].
91 Munoz-Rojas MV, Vieira T, Costa R, et al. Intrathecal enzyme replacement therapy in a patient with mucopolysaccharidosis type I and symptomatic spinal cord compression. Am J Med Genet A. Oct. 1. 2008;146A(19):2538-44. [pmid: 18792977].
92 Munoz-Rojas MV, Horovitz DD, Jardim LB, et al. Intrathecal administration of recombinant human N-acetylgalactosamine 4-sulfatase to a MPS VI patient with pachymeningitis cervicalis. Mol Genet Metab. Apr. 2010;99(4):346-50. [pmid: 20036175].
93 Warnock DG, Ortiz A, Mauer M, et al. Renal outcomes of agalsidase beta treatment for Fabry disease: role of proteinuria and timing of treatment initiation. Nephrol Dial Transplant. 2011. Jul. 29. [pmid: 21804088].
94 Mistry PK, Deegan P, Vellodi A, et al. Timing of initiation of enzyme replacement therapy after diagnosis of type 1 Gaucher disease: effect on incidence of avascular necrosis. Br J Haematol. Nov. 2009;147(4):561-70. [pmid: 19732054].
95 Mistry PK, Sadan S, Yang R, et al. Consequences of diagnostic delays in type 1 Gaucher disease: the need for greater awareness among hematologists-oncologists and an opportunity for early diagnosis and intervention. Am J Hematol. Aug. 2007;82(8):697-701. [pmid: 17492645].
96 Chien YH, Lee NC, Huang HJ, et al. Later-onset Pompe disease: early detection and early treatment initiation enabled by newborn screening. J Pediatr. Jun. 2011;158(6):1023-7 e1. [pmid: 21232767].
97 Dixon CA, Anderson JB, Ruddy RM, et al. Infantile-onset Pompe disease: a diagnosis not to miss. Pediatr Emerg Care. Apr. 2010;26(4):293-5. [pmid: 20386415].
98 Chien YH, Lee NC, Thurberg BL, et al. Pompe disease in infants: improving the prognosis by newborn screening and early treatment. Pediatrics. Dec. 2009;124(6):e1116-25. [pmid: 19948615].
99 But WM, Lee SH, Chan AO, et al. Enzyme replacement therapy for infantile Pompe disease during the critical period and identification of a novel mutation. Hong Kong Med J. Dec. 2009;15(6):474-7. [pmid: 19966354].
100 Chien YH, Chiang SC, Zhang XK, et al. Early detection of Pompe disease by newborn screening is feasible: results from the Taiwan screening program. Pediatrics. Jul. 2008;122(1):e39-45. [pmid: 18519449].
101 Kishnani PS, Goldenberg PC, DeArmey SL, et al. Cross-reactive immunologic material status affects treatment outcomes in Pompe disease infants. Mol Genet Metab. Jan. 2010;99(1):26-33. [pmid: 19775921].
102 Schulze-Frenking G, Jones SA, Roberts J, et al. Effects of enzyme replacement therapy on growth in patients with mucopolysaccharidosis type II. J Inherit Metab Dis. Feb. 2011;34(1):203-8. [pmid: 20978944].
103 Weinreb N, Barranger J, Packman S, et al. Imiglucerase (Cerezyme) improves quality of life in patients with skeletal manifestations of Gaucher disease. Clin Genet. Jun. 2007;71(6):576-88. [pmid: 17539908].
104 Masek BJ, Sims KB, Bove CM, et al. Quality of life assessment in adults with type 1 Gaucher disease. Qual Life Res. May. 1999;8(3):263-8. [pmid: 10472157].
105 Hayes RP, Grinzaid KA, Duffey EB, et al. The impact of Gaucher disease and its treatment on quality of life. Qual Life Res. Aug. 1998;7(6):521-34. [pmid: 9737142].
106 Watt T, Burlina AP, Cazzorla C, et al. Agalsidase beta treatment is associated with improved quality of life in patients with Fabry disease: findings from the Fabry Registry. Genet Med. Nov. 2010;12(11):703-12. [pmid: 20885332].
107 Soutar RL, Mercer J, Wraith JE. Impact of 144 weeks of laronidase therapy on body functions, endurance and general well-being in a Hurler-Scheie patient. J Inherit Metab Dis. Aug. 2006;29(4):590. [pmid: 16830264].
108 Giraldo P, Irun P, Alfonso P, et al. Evaluation of Spanish Gaucher disease patients after a 6-month imiglucerase shortage. Blood Cells Mol Dis. Jan. 15. 2011;46(1):115-8. [pmid: 20934891].
109 Goldblatt J, Fletcher JM, McGill J, et al. Enzyme replacement therapy “drug holiday”: results from an unexpected shortage of an orphan drug supply in Australia. Blood Cells Mol Dis. Jan. 15. 2011;46(1):107-10. [pmid: 20684886].
110 McGill JJ, Inwood AC, Coman DJ, et al. Enzyme replacement therapy for mucopolysaccharidosis VI from 8 weeks of age–a sibling control study. Clin Genet. May. 2010;77(5):492-8. [pmid: 19968667].
111 Hollak CE, de Fost M, van Dussen L, et al. Enzyme therapy for the treatment of type 1 Gaucher disease: clinical outcomes and dose - response relationships. Expert Opin Pharmacother. Nov. 2009;10(16):2641-52. [pmid: 19743939].
112 Grabowski GA, Kacena K, Cole JA, et al. Dose-response relationships for enzyme replacement therapy with imiglucerase/alglucerase in patients with Gaucher disease type 1. Genet Med. Feb. 2009;11(2):92-100. [pmid: 19265748].
113 Wilson C, Spearing R, Teague L, et al. The outcome of clinical parameters in adults with severe Type I Gaucher disease using very low dose enzyme replacement therapy. Mol Genet Metab. Sep–Oct. 2007;92(1–2):131-6. [pmid: 17604204].
114 Heitner R, Arndt S, Levin JB. Imiglucerase low-dose therapy for paediatric Gaucher disease–a long-term cohort study. S Afr Med J. Aug. 2004;94(8):647-51. [pmid: 15352589].
115 Altarescu G, Schiffmann R, Parker CC, et al. Comparative efficacy of dose regimens in enzyme replacement therapy of type I Gaucher disease. Blood Cells Mol Dis. Aug. 2000;26(4):285-90. [pmid: 11042029].
116 Elstein D, Abrahamov A, Itzchaki M, et al. Commentary: low-dose high-frequency enzyme replacement therapy prevents fractures without complete suppression of painful bone crises in patients with severe juvenile onset type I Gaucher disease. Blood Cells Mol Dis. Sep. 1998;24(3):303-5. discussion 6–8. [pmid: 10087988].
117 Elstein D, Abrahamov A, Hadas-Halpern I, et al. Low-dose low-frequency imiglucerase as a starting regimen of enzyme replacement therapy for patients with type I Gaucher disease. QJM. Jul. 1998;91(7):483-8. [pmid: 9797931].
118 Hollak CE, Goudsmit R, van Oers MH. Low-dose versus high-frequency regimens in Gaucher’s disease. Lancet. Feb. 10. 1996;347(8998):406-7. [pmid: 8598739].
119 Elstein D, Hadas-Halpern I, Itzchaki M, et al. Effect of low-dose enzyme replacement therapy on bones in Gaucher disease patients with severe skeletal involvement. Blood Cells Mol Dis. 1996;22(2):104-11. discussion 12–4. [pmid: 8931951].
120 Lubanda JC, Anijalg E, Bzduch V, et al. Evaluation of a low dose, after a standard therapeutic dose, of agalsidase beta during enzyme replacement therapy in patients with Fabry disease. Genet Med. Apr. 2009;11(4):256-64. [pmid: 19265719].
121 Wenger DA, Coppola S, Liu SL. Lysosomal storage disorders: diagnostic dilemmas and prospects for therapy. Genet Med. Nov–Dec. 2002;4(6):412-9. [pmid: 12509711].
122 McIntyre FL. One in a million: when extraordinary cases occur in an ordinary practice. J Fam Pract. Jan. 1993;36(1):17-8. [pmid: 8419498].
123 Wraith JE. The clinical presentation of lysosomal storage disorders. Acta Neurol Taiwan. Sep. 2004;13(3):101-6. [pmid: 15508935].
124 Phillips WR. Zebras on the common: rare conditions in family practice. J Am Board Fam Pract. 2004;17:283-6. [pmid: 15243016].