# Peer Reviewers

Barbara Burton, M.D.

Professor of Pediatrics

Feinberg School of Medicine and

Director, Adult Phenylketonuria (PKU) Program

Children’s Memorial Research Center

Chicago, IL

Robert Steiner, M.D.

Credit Unions for Kids Professor of Pediatric Research and Vice Chair for Research

Oregon Health & Science University

Portland, OR

Jeanine Utz, Pharm.D., B.C.O.P., B.C.P.S.

Medication Therapy Management, Advanced Therapies

Adjunct Assistant Professor

Department of Experimental and Clinical Pharmacology

University of Minnesota, Fairview

Minneapolis, MN