# Findings

## Guiding Question 1 What FDA-approved enzyme-replacement therapy (ERT) products are available for lysosomal storage diseases (LSDs)?

All commercially available ERT products in the United States were approved under stipulations of the FDA Orphan Drug Act (ODA) of 1983, which provides for granting special status to a product to treat a rare disease or condition upon request of a sponsor (www.fda.gov/RegulatoryInformation/Legislation/FederalFoodDrugandCosmeticActFDCAct/SignificantAmendmentstotheFDCAct/OrphanDrugAct/default.htm).

According to the ODA, a product intended to treat a rare disease or condition must meet certain criteria, particularly that the disease or condition for which the drug is intended affects fewer than 200,000 people in the United States or, if the drug is a vaccine, diagnostic drug, or preventive drug, the persons to whom the drug will be administered in the United States are fewer than 200,000 per year. This status is referred to as orphan designation. The approval of an orphan designation request does not alter the standard regulatory requirements and process for obtaining marketing approval. The safety and efficacy of a compound must be established through adequate and well-controlled studies.

Due to the massive financial investment required to produce orphan drugs, prior to the passage of the ODA, very few companies invested in the development of these drugs. Additionally, because the target population for orphan drugs is extremely small, the long-term return on investment for these drugs is extremely low. The ODA provides pharmaceutical companies who develop orphan drugs with a tax credit to help offset the cost to conduct clinical trials. The Act also grants a 7-year period of market exclusivity to prevent other companies from developing and competing with similar products.

### What are the Clinical Indications for Each FDA-Approved ERT Product?

Table 2 lists nine FDA-approved ERT products and the clinical indications for each, according to the FDA-approved prescribing information. Off-label use is not relevant for these agents, with the exception of dose regimen variations, for example in patients with type I Gaucher disease.32–34

Table 2 FDA-approved prescribing information for enzyme-replacement therapy products for lysosomal storage diseases

Disease | Product (Generic Name) | Manufacturer | FDA Approval Date | Clinical Indication From the FDA-Approved Prescribing Information (Source)
Fabry Disease | Fabrazyme® (agalsidase beta) | Genzyme Corporation | April 2003 | Fabrazyme is indicated for use in patients with Fabry disease. (www.fabrazyme.com/hcp/pi/fz_us_hc_pi.pdf)
Type 1 Gaucher disease | Cerezyme® (imiglucerase) | Genzyme Corporation | May 1994 | Cerezyme (imiglucerase for injection) is indicated for long-term enzyme-replacement therapy for pediatric and adult patients with a confirmed diagnosis of type 1 Gaucher disease that results in one or more of the following conditions:; - anemia; - thrombocytopenia; - bone disease; - hepatomegaly or splenomegaly; (www.cerezyme.com/~/media/Files/CerezymeUS/pdf/cerezyme_pi.pdf)
Type 1 Gaucher disease | VPRIV™™ (velaglucerase alfa) | Shire Human Genetic Therapies, Inc. | March 2010 | VPRIV (velaglucerase alfa for injection) is a hydrolytic lysosomal glucocerebroside-specific enzyme indicated for long-term enzyme-replacement therapy (ERT) for pediatric and adult patients with type 1 Gaucher disease. (www.accessdata.fda.gov/drugsatfda_docs/label/2010/022575lbl.pdf)
Type 1 Gaucher disease | Elelyso™ (taliglucerase) | Pfizer Labs | May 2012 | ELELYSO™ (taliglucerase alfa) for injection is a hydrolytic lysosomal glucocerebroside-specific enzyme indicated for long-term enzyme replacement therapy (ERT) for adults with a confirmed diagnosis of Type 1 Gaucher disease. (www.elelyso.com/pdf/ELELYSO_Prescribing_Information.pdf)
Glycogen Storage Disease type II (Pompe disease) | Myozyme® (alglucosidase alfa) | Genzyme Corporation | April 2006 | Myozyme (alglucosidase alfa) is indicated for use in patients with Pompe disease. Myozyme has been used in patients with infantile-onset Pompe disease, whereas use of Myozyme in patients with other forms of Pompe disease has not been adequately studied. (www.accessdata.fda.gov/drugsatfda_docs/label/2008/125141_74lbl.pdf)
Glycogen Storage Disease type II (Pompe disease) | Lumizyme® (alglucosidase alfa) | Genzyme Corporation | May 2010 | Lumizyme (alglucosidase alfa) is a lysosomal glycogen-specific enzyme indicated for patients 8 years and older with late (non-infantile) onset Pompe disease who do not have evidence of cardiac hypertrophy. The safety and efficacy of Lumizyme have not been evaluated in controlled clinical trials in infantile-onset patients, or in late (non-infantile) onset patients less than 8 years of age. (www.accessdata.fda.gov/drugsatfda_docs/label/2010/125291lbl.pdf)
MPS I (Hurler, Hurler-Scheie, or Scheie syndrome) | Aldurazyme® (laronidase) | Genzyme Corporation | April 2003 | Aldurazyme is a hydrolytic lysosomal glycosaminoglycan (GAG)-specific enzyme indicated for patients with Hurler and Hurler-Scheie forms of Mucopolysaccharidosis I (MPS I) and for patients with the Scheie form who have moderate to severe symptoms. The risks and benefits of treating mildly affected patients with the Scheie form have not been established. Aldurazyme has not been evaluated for effects on the central nervous system manifestations of the disorder. (www.aldurazyme.com/pdf/az_us_hc_pi.pdf)
MPS II (Hunter disease) | Elaprase® (idursulfase intravenous) | Shire Human Genetic Therapies, Inc. | July 2006 | Elaprase is indicated for patients with Hunter syndrome (Mucopolysaccharidosis II, MPS II). (www.elaprase.com/pdf/Elaprase_US_PI_v6.pdf)
MPS VI (Maroteaux-Lamy syndrome) | Naglazyme™ (galsulfase) | BioMarin Pharmaceutical, Inc. | June 2005 | Naglazyme is a hydrolytic lysosomal glycosaminoglycan (GAG)-specific enzyme indicated for patients with Mucopolysaccharidosis VI (MPS VI; Maroteaux-Lamy syndrome). (www.naglazyme.com/en/documents/Naglazyme_Prescribing_Information.pdf)

The indications shown in Table 2 are specific to the disease in question and are based on evidence from clinical studies, some of which are shown in summary tables under Guiding Question 3 of this Technical Brief. For example, in three published clinical studies of agalsidase beta for Fabry disease (reviewed later), a key endpoint was the extent of globotriaosylceramide (GL-3) inclusions in the capillary endothelium of the kidney, heart, and skin, measured by light microscopy in biopsy specimens.35–37 In a randomized, placebo-controlled trial, accumulation of GL-3 in these cells was considered to be a surrogate marker for the subsequent development of renal, cardiac, and cerebrovascular disease, which lead to high morbidity and premature mortality.36 A subsequent postapproval randomized, double-blind placebo-controlled trial was required by FDA to demonstrate clinical benefit. This trial examined correlations between inclusion clearance and subsequent composite clinical outcomes related to renal, cardiac and cerebrovascular disease.35

The first ERT product for type I Gaucher disease (alglucerase, no longer marketed) received approval based on effects on surrogate markers, including hemoglobin levels and platelet counts; splenic and hepatic volumes measured by computed tomography (CT) or magnetic resonance imaging (MRI); and, skeletal involvement reflected by serum acid phosphatase activity.38 As shown later in this Technical Brief, subsequent studies for the more recently approved products for type I Gaucher disease (imiglucerase, velaglucerase, taliglucerase alfa) used similar disease surrogates, as well as clinical outcomes such as bone pain, bone crisis, pathologic fractures, mobility, and quality of life (SF-36 general health survey).39–44

As shown in Table 2, and the summary tables for clinical studies of these diseases under Guiding Question 3, the other commercially available ERT products received approval based on their effects on disease-specific clinical outcomes, including, but not limited to, walking (laronidase for MPS I, idursulfase (intravenous) for MPS II, galsulfase for MPS VI) or stair-climbing capacity (galsulfase) and pulmonary capacity and function (alglucosidase alfa for Pompe disease, laronidase for MPS I).

### What are the Potential Benefits of ERT for LSDs?

Potential beneficial responses to ERT are outlined according to disease in Table 3, based on information obtained from the FDA-approved product labels and from narrative review articles.1, 2, 7–9, 12, 16, 45, 46

Table 3 Potential beneficial responses to ERT for lysosomal storage diseases

Disease | Outcome Measure 1, 2, 7–9, 12, 16, 45, 46
Fabry Disease | - Renal function; - Vascular lesions; - Myocardial function; - Nerve fiber conduction; - Neuropathic pain; - Tolerance to cold and heat; - Exercise tolerance; - Quality of life
Type 1 Gaucher disease | - Hepatic or splenic volume; - Hematological measures; - Bone manifestations; - Growth benefits
Glycogen Storage Disease type II (Pompe disease) | - Lifespan; - Cardiac symptoms; - Myocardial function; - Skeletal muscle function; - Walking ability; - Sleep disordered breathing; - Respiratory or pulmonary function; - Quality of life
MPS I H-S and S (Hurler, Hurler-Scheie, or Scheie syndrome) disease) | - Urinary glycosaminoglycan levels; - Hepatic or splenic volume; - Airway patency and sleep apnea; - Myocardial function; - Range of motion in joints; - Growth rate; - 6-minute walk test
MPS II (Hunter disease) | - Urinary glycosaminoglycan levels; - Hepatic and splenic volume; - Airway patency and sleep apnea; - Myocardial function; - Range of motion in joints; - Growth rate; - 6-minute walk test
MPS VI (Maroteaux-Lamy syndrome) | - Urinary glycosaminoglycan levels; - Hepatic and splenic volume; - Airway patency and sleep apnea; - Myocardial function; - Range of motion in joints; - Growth rate; - 6-minute walk test; - 12-minute walk test; - Stair climbing test; - Pulmonary function; - Endurance; - Growth

According to interviews with Key Informant clinical experts, the responses to ERT may vary within each LSD for which it is indicated, related to the clinical manifestations and stage of disease at the time ERT is initiated. Our Key Informants further suggested that the optimal timing of ERT initiation is not established, although earlier in the disease course is surmised to be better than later.

### What are the Potential Safety Issues and Harms With ERT?

The FDA-approved prescribing information for each ERT product indicates infusion-associated adverse events may occur in recipients. These include pyrexia, chills, hypertension, tachycardia, cutaneous reactions (rash, pruritis, erythema, urticaria), burning, swelling, headache, nausea, fatigue, malaise, joint pain, dyspnea, facial edema, dizziness, bronchospasm, and others (Table 4).

Table 4 Adverse effects of ERT reported in the FDA-approved label

Disease | Generic Name | Infusion-Related | IgG-Positivity | Black Box Warning
Fabry Disease | agalsidase beta | • | •
Type 1 Gaucher disease | imiglucerase velaglucerase taliglucerase | • | •
Glycogen Storage Disease type II (Pompe disease) | alglucosidase alfa (two products with same generic name) | • | • | •
MPS I H-S and S (Hurler, Hurler-Scheie, or Scheie syndrome) | laronidase | • | • | •
MPS II (Hunter disease) | idursulfase (intravenous) | • | • | •
MPS VI (Maroteaux-Lamy syndrome) | galsulfase | • | •

The FDA-approved label for each ERT product also reports immunogenic effects, primarily elicitation of IgG-type antibodies, including neutralizing antibodies, in varying proportions of study subjects (Table 4). The prescribing information for these products cautions that interpretation of immunogenicity results is affected by the sensitivity and specificity of the assay, and that the incidence of antibody positivity may be influenced by a number of factors related to assay methodology, sample handling, timing of sample collection relative to dosing, concomitant medications, and underlying disease. The influence of elicited IgG antibodies on long-term efficacy of ERT products was not reported in the clinical studies cited under Guiding Question 3 in this Technical Brief.

Black box warnings appear on the FDA-approved label for four ERT products (alglucosidase alfa [Myozyme® and Lumizyme®]; idursulfase (intravenous) [Elaprase®]; laronidase [Aldurazyme®]), indicating life-threatening anaphylactic reactions have been observed in some patients during infusion (Table 4). The label for a fourth product, agalsidase beta [Fabrazyme®] indicates that life-threatening anaphylactic reactions and severe allergic reactions have been observed in some patients during infusions, but the information is not specifically included as a black box warning.

The prescribing information for each product reports adverse events were noted in a low proportion of ERT recipients, but none have been attributed to a specific action of the glycoprotein itself. This concurs with the clinical experience reported by the Key Informants for this Technical Brief, who reported infusion-related reactions and immunogenic events in their patients; it also concurs with results reported in the clinical studies summarized under Guiding Question 3.

## Guiding Question 2 What is the context in which each FDA-approved ERT product is used?

### What are the FDA-Approved Dose Regimens for Each ERT Product?

The dose regimen specified in the FDA-approved label for each ERT product is shown in Table 5. All ERT products are infused intravenously, typically over periods of 1 to 4 hours, as specified.

Table 5 FDA-approved label dose regimens for ERT products

Disease | Product | Dose Regimen (Link)
Fabry Disease | Fabrazyme® (agalsidase beta) | - The recommended dosage of Fabrazyme is 1 mg/kg body weight infused every two weeks as an intravenous (IV) infusion. Patients should receive antipyretics prior to infusion.; - The initial IV infusion rate should be no more than 0.25 mg/min (15 mg/hr). The infusion rate may be slowed in the event of infusion reactions. After patient tolerance to the infusion is well established, the infusion rate may be increased in increments of 0.05 to 0.08 mg/min (increments of 3 to 5 mg/hr) with each subsequent infusion. For patients weighing < 30 kg, the maximum infusion rate should remain at 0.25 mg/min (15 mg/hr). For patients weighing ≥ 30 kg, the administration duration should not be less than 1.5 hours (based on individual patient tolerability).; - Patients who have had a positive skin test to Fabrazyme or who have tested positive for anti-Fabrazyme IgE may be successfully re-challenged with Fabrazyme. The initial re-challenge administration should be a low dose at a lower infusion rate, e.g., 1/2 the therapeutic dose (0.5 mg/kg) at 1/25 the initial standard recommended rate (0.01 mg/min).; - Once a patient tolerates the infusion, the dose may be increased to reach the approved dose of 1 mg/kg and the infusion rate may be increased by slowly titrating upwards (doubled every 30 minutes up to a maximum rate of 0.25 mg/min), as tolerated.; (www.fabrazyme.com/hcp/pi/fz_us_hc_pi.pdf)
Type 1 Gaucher disease | Cerezyme® (imiglucerase) | - Cerezyme® (imiglucerase for injection) is administered by intravenous infusion over 1–2 hours. Dosage should be individualized to each patient.; - Initial dosages range from 2.5 U/kg of body weight 3 times a week to 60U/kg once every 2 weeks. 60 U/kg every 2 weeks is the dosage for which the most data are available. Disease severity may dictate that treatment be initiated at a relatively high dose or relatively frequent administration.; - Dosage adjustments should be made on an individual basis and may increase or decrease, based on achievement of therapeutic goals as assessed by routine comprehensive evaluations of the patient’s clinical manifestations.; (www.cerezyme.com/~/media/Files/CerezymeUS/pdf/cerezyme_pi.pdf)
Type 1 Gaucher disease | VPRIV™ (velaglucerase alfa) | - 60 Units/kg administered every other week as a 60-minute intravenous infusion.; - Patients currently being treated with imiglucerase for Gaucher disease can be switched to VPRIV. Patients previously treated on a stable dose of imiglucerase are recommended to begin treatment with VPRIV at that same dose when they switch from imiglucerase to VPRIV.; - Physicians can make dosage adjustments based on achievement and maintenance of each patient’s therapeutic goals. Clinical trials have evaluated doses ranging from 15 Units/kg to 60 Units/kg every other week.; (www.accessdata.fda.gov/drugsatfda_docs/label/2010/022575lbl.pdf)
Type 1 Gaucher disease | Elelyso™ (taliglucerase) | - The recommended dose is 60 Units/kg of body weight administered once every 22 weeks as a 60–120 minute intravenous infusion.; - Patients currently being treated with imiglucerase for Type 1 Gaucher disease can be switched to ELELYSO. Patients previously treated on a stable dose of imiglucerase are recommended to begin treatment with ELELYSO at that same dose when they switch from imiglucerase to ELELYSO.; - Dosage adjustments can be made based on achievement and maintenance of each patient’s therapeutic goals. Clinical studies have evaluated dose ranges from 11 Units/kg to 73 Units/kg every other week.; - The initial infusion rate should be 11.3 mL/min. After patient tolerability to the infusion rate is established, the rate of infusion may be increased to 2.3 mL/min. The total volume of the infusion solution should be delivered over a period of no less than 1 hour.; (www.elelyso.com/pdf/ELELYSO_Prescribing_Information.pdf)
Glycogen Storage Disease type II (Pompe disease) | Myozyme® (alglucosidase alfa) | - The recommended dosage regimen of Myozyme is 20 mg/kg body weight administered every 2 weeks as an intravenous infusion. The total volume of infusion is determined by the patient’s body weight and should be administered over approximately 4 hours.; - Infusions should be administered in a step-wise manner using an infusion pump. The initial infusion rate should be no more than 1 mg/kg/hr. The infusion rate may be increased by 2 mg/kg/hr every 30 minutes, after patient tolerance to the infusion rate is established, until a maximum rate of 7 mg/kg/hr is reached. Vital signs should be obtained at the end of each step. If the patient is stable, Myozyme may be administered at the maximum rate of 7 mg/kg/hr until the infusion is completed. The infusion rate may be slowed and/or temporarily stopped in the event of infusion reactions.; (www.accessdata.fda.gov/drugsatfda_docs/label/2008/125141_74lbl.pdf)
Glycogen Storage Disease type II (Pompe disease) | Lumizyme® (alglucosidase alfa) | - The recommended dosage of Lumizyme is 20 mg/kg body weight administered every 2 weeks as an intravenous infusion.; - The total volume of infusion is determined by the patient’s body weight and should be administered over approximately 4 hours. Infusions should be administered in a step-wise manner using an infusion pump.; - The initial infusion rate should be no more than mg/kg/hr. The infusion rate may be increased by 2 mg/kg/hr every 30 minutes, after patient tolerance to the infusion rate is established, until a maximum rate of 7 mg/kg/hr is reached. Vital signs should be obtained at the end of each step. If the patient is stable, Lumizyme may be administered at the maximum rate of 7 mg/kg/hr until the infusion is completed. The infusion rate may be slowed or temporarily stopped in the event of infusion reactions.; (www.accessdata.fda.gov/drugsatfda_docs/label/2010/125291lbl.pdf)
MPS I H-S and S (Hurler, Hurler-Scheie, or Scheie syndrome) | Aldurazyme® (laronidase) | - The recommended dosage regimen of Aldurazyme is 0.58 mg/kg of body weight administered once weekly as an intravenous (IV) infusion.; - Pretreatment is recommended 60 minutes prior to the start of the infusion and may include antihistamines, antipyretics, or both.; - The final volume of the infusion is determined by the patient’s body weight. Patients with a body weight of 20 kg or less should receive a total volume of 100 mL. Patients with a body weight greater than 20 kg should receive a total volume of 250 mL. For patients with underlying cardiac or respiratory compromise and weighing up to 30 kg, physicians may consider diluting Aldurazyme in a volume of 100 mL and administering at a decreased infusion rate.; (www.aldurazyme.com/pdf/az_us_hc_pi.pdf)
MPS II (Hunter disease) | Elaprase® (idursulfase intravenous) | - The recommended dosage regimen of Elaprase is 0.5 mg/kg of body weight administered every week as an intravenous infusion.; - Elaprase is a concentrated solution for intravenous infusion.; - The total volume of infusion may be administered over a period of 1 to 3 hours. Patients may require longer infusion times due to infusion reactions; however, infusion times should not exceed 8 hours.; - The initial infusion rate should be 8 mL/hr for the first 15 minutes. If the infusion is well tolerated, the rate may be increased by 8 mL/hr increments at 15 minute intervals in order to administer the full volume within the desired period of time. However, at no time should the infusion rate exceed 100 mL/hr. The infusion rate may be slowed and/or temporarily stopped, or discontinued for that visit, based on clinical judgment, if infusion reactions were to occur. Elaprase should not be infused with other products in the infusion tubing.; (www.elaprase.com/pdf/Elaprase_US_PI_v6.pdf)
MPS VI (Maroteaux-Lamy syndrome) | Naglazyme™ (galsulfase) | - The recommended dosage regimen of Naglazyme is 1 mg per kg of body weight administered once weekly as an intravenous infusion.; - Pretreatment with antihistamines with or without antipyretics is recommended 30 to 60 minutes prior to the start of the infusion.; - The total volume of the infusion should be delivered over a period of time of no less than 4 hours. The initial infusion rate should be 6 mL per hour for the first hour. If the infusion is well tolerated, the rate of infusion may be increased to 80 mL per hour for the remaining 3 hours. The infusion time can be extended up to 20 hours if infusion reactions occur.; - For patients 20 kg and under or those who are susceptible to fluid volume overload, physicians may consider diluting Naglazyme in a volume of 100 mL. The infusion rate (mL per min) should be decreased so that the total infusion duration remains no less than 4 hours.; (www.naglazyme.com/en/documents/Naglazyme_Prescribing_Information.pdf)

The dose regimens shown in Table 5 reflect those in the FDA-approved prescribing information for each agent. According to the Key Informants, dose optimization is of significant interest, particularly determining a minimum effective dose for each disease, given the burden on the family unit of weekly or fortnightly infusions. Published studies (see findings for Guiding Question 3) have evaluated more than one dose regimen for some ERT products, including agalsidase beta for Fabry disease;47 imiglucerase for type I Gaucher disease;41, 48 laronidase for MPS I;49 idursulfase (intravenous) for MPS II;50, 51 and galsulfase for MPS VI.52, 53

### Where and By Whom is ERT Administered?

In the United States, ERT has typically been administered in an outpatient infusion clinic under the direction of a physician and team experienced in the use of these agents.54 Such well-controlled settings are initially required to ensure immediate access to care to address serious infusion-associated adverse reactions, particularly immediate-type (IgE-mediated) hypersensitivity, or anaphylactic, events. Furthermore, medically fragile patients may more appropriately receive infusions in an inpatient or short stay infusion unit setting.55

Because these agents must be administered on a weekly or every other weekly basis for the life of the patient, ERT can be onerous, leading to missed school or workplace absence on the day it is received, and ultimately missed doses. To lessen the burden on patients and their families, some patients may be transitioned to home therapy.56–58 Home infusion of ERT was initially studied in patients with type I Gaucher disease.59 It has been reported as an option for patients with Fabry disease,60 MPS I,61 and MPS II, and MPS VI.56, 62, 63 However, patients with infantile Pompe disease may not be able to transfer to home care because of an increased risk for serious adverse events during an infusion.55 In general, the outcomes measured in these studies and the follow-up durations were similar to those reported by disease in the clinical studies summarized under Guiding Question 3. Safety was the main focus of most home infusion studies, as the patients had already been receiving ERT in a more controlled setting.

In the United States, individual access to home therapy is typically determined by the patient’s health insurance plan.64 Although the chronology may vary by patient and disease, transition to home therapy typically is considered after an initial 6 months of clinic treatment free from infusion-associated reactions.56, 62, 65 The attending physician determines whether patients are recommended for home infusion. Home infusions are conducted under the care of trained infusion personnel, though the physician is available via phone if additional direction is necessary.62 Essential elements of a home infusion program include a home health care team, a defined protocol with careful patient selection, good vascular access either through a peripheral line or central access device, and a detailed management plan for infusion-associated reactions and anaphylaxis.62, 65 An algorithm has been proposed for home infusion to treat MPS II, based on data from the international Hunter Outcome Survey.66 This protocol commences ERT in clinic, with subsequent evaluation for home therapy. If successful, the patient is referred to a home care team for assessment, with agreement of all parties for transition, and followed by initiation of home treatment.65 According to this approach, a patient who does not fulfill criteria for home therapy will continue treatment in clinic.

### What Adjunct Treatments Are Used With Each FDA-Approved ERT Product?

Therapeutic management of LSDs comprises measures that address specific symptoms of each disease, but offering no possibility for cure.1–3, 15, 16 Similar organ-specific manifestations may appear in various combinations as a function of disease and disease stage, including the gastrointestinal tract, the central nervous system, the upper and lower respiratory tract, the visual system, the musculoskeletal system, and the hematopoietic system. For example, untreated patients with Type 1 Gaucher disease, the most common LSD, may develop hepatomegaly or splenomegaly, anemia, thrombocytopenia, impaired lung function, acute or chronic severe bone pain, avascular necrosis, and have growth impairment and pubertal delay.17 Supportive care prior to development of ERT may have comprised combinations of therapies that could include blood transfusion, bed rest, analgesia, anti-inflammatory agents, hyperbaric oxygen, and surgery (splenectomy, orthopedic procedures). In the age of ERT, however, many of these are no longer used nor recommended (e.g., splenectomy).

In addition to disease-specific adjunct measures, a number of common drugs may be used to prevent or treat infusion-associated reactions, some examples of which are shown in Table 6.^62^ Dose regimens for antihistamines, corticosteroids and epinephrine are typically age-dependent, and may vary by physician choice, experience, or availability. Those presented in Table 6 have been reported in the context of home infusion of idursulfase (intravenous).62 Given the common immune pathogenesis and physiology involved in infusion-associated reactions, and mechanism of action of the drugs, these treatments will be effective regardless of the ERT in question.

Table 6 Drugs potentially used for the treatment of ERT infusion-associated reactions

Severity of Reaction | Antipyretic | Antihistaminic | Anti-inflammatory | Sympathicomimetic | H2 Receptor Antagonist
Mild | Acetaminophen Ibuprofen | Chlorpheniramine Hydroxyzine | NA | NA | NA
Moderate | Acetaminophen Ibuprofen | Chlorpheniramine (IV) | Hydrocortisone (IV) | NA | NA
Severe (anaphylaxis) | Acetaminophen Ibuprofen | Chlorpheniramine (IV) | Hydrocortisone (IV) | Epinephrine (IM) Albuterol (nebulized) | Ranitidine (IV)

IM = intramuscular; IV = intravenous; NA = not applicable

## Guiding Question 3 What published and unpublished studies have reported on the use and safety of this intervention?

### Published Clinical Studies

#### Search Results

The primary goal of the literature search was to show the relative scope and extent of studies that have been published since 1990. MEDLINE®, EMBASE®, the Cochrane Controlled Trial Database, and the Health Technology Assessment Database were searched electronically, as shown in Appendix A.

An initial electronic search encompassing the period January 1990 through September 16, 2011 yielded a total of 585 citations. During peer review of the draft report, the search was updated for the period September 16, 2011 through April 24, 2012, yielding an additional 150 items. Among all 735 citations, 361 were excluded as not relevant by title and abstract screen, leaving 374; four additional citations were identified through hand searches of bibliographies or at peer review, bringing the total to 378 shown in Table 7. Clinical studies and registry reports were retrieved for full-text (second-level) examination. Appendix E contains a resource bibliography of all the articles that we enumerate in Table 7.

Table 7 Second-level literature screen results

Study Type | Fabry Disease | Type 1 Gaucher Disease | Type II Glycogen Storage Disease (Pompe) | MPS I | MPS II | MPS VI | Total
RCT/Prospective phase I/II | 8 | 7 | 8 | 5 | 4 | 3 | 35
Case Series | 29 | 53 | 20 | 10 | 7 | 1 | 120
Case Reports | 16 | 14 | 13 | 12 | 8 | 6 | 69
Guidelines | 4 | 3 | 1 | 1 | 1 | 1 | 11
Registry Reports | 3 | 4 | 0 | 0 | 3 | 1 | 11
Reviews | 41 | 32 | 22 | 18 | 12 | 7 | 132
Total | 101 | 113 | 64 | 46 | 35 | 19 | 378

Figure 1 is a PRISMA (Preferred Reporting Items for Systematic Reviews and Meta-Analyses)67 diagram depicting the flow of articles through this Technical Brief.

Figure 1 PRISMA (Preferred Reporting Items for Systematic Reviews and Meta-Analyses) diagram depicting the flow of articles through this Technical Brief

Figure 1 is a PRISMA (Preferred Reporting Items for Systematic Reviews and Meta-Analyses) diagram depicting the flow of articles through this Brief. Seven-hundred and thirty-five articles were identified though database searching and screened. Three-hundred and sixty-one references were excluded on titles and abstracts and 374 underwent full-text review. Four additional articles were identified from the grey literature. A total of 332 articles were excluded at full-text review: 120 case series, 69 case reports, 11 guidelines, and 132 reviews. Forty-six unique articles were included: 35 prospective/RCT reports and 11 registry reports.

#### Evidence Compilations

In Table 8 through Table 13, we present information on clinical outcomes from a total of 35 RCTs and other prospective studies on each disease and ERT product. Because we had a sufficient number of RCTs and prospective studies to adequately map the clinical evidence, we did not include case series or case reports in the tables.

Table 8 Selected clinical studies of agalsidase beta for the treatment of Fabry Disease

Author, Year, Country, Sample Size | Study Design | Treatment Groups and Dose | Disease Stage/Type | Mean age at Study Onset (range) Yrs | Length of Followup (wks) | Substrate Level | Substrate Deposits | Renal Function | Cardiac Function | Pain Scores | Cerebrovascular | Growth | Quality of Life
Vedder47 2008, Netherlands n=13 n=21 | dose-optimization study | 1. 0.2 mg/kg every other week (eow); 2. 1.0 mg/kg eow | no information provided | 1. 1) 49; (25–73); 2. 48; (27–70) | 52 | • | | • | •
Wraith37 2008, international n=16 | open-label study in children | 1 mg/kg eow | symptomatic | 12 (9–12) | 48 | • | | • | • | | | • | •
Banikazemi35 2007, international agalsidase beta: n=51 placebo: n=31 | randomized double blind, placebo controlled trial | 1 mg/kg eow placebo | symptomatic | 47±10 44±9 | up to 152 | | | • | • | | •
Germain36 2007, international n=58 | open-label extension study | 1 mg/kg eow | symptomatic | 31 (17–62) | up to 234 | • | | • | • | •
Tahir71 2007, USA N = 11 | open-label | 1 mg/kg eow | symptomatic | 19–58 | 120 | | | •
Vedder70 2007, Netherlands n=16 | open-label randomized, controlled trial | 0.2 mg/kg eow | treatment groups stratified by disease severity | 48 (24–76) | 52–104 | • | | • | • | •
Eto^68^2005, Japan n=13 | open-label Phase II bridging study | 1 mg/kg eow | symptomatic | 27 (16–34) | 20 | • | | •
Eng^69^2001, international n=58 agalsidase beta: n=29 placebo: n=29 | randomized double blind, placebo controlled trial | 1 mg/kg eow placebo | symptomatic | 32±9 28±11 | 20 | • | • | | | •

Table 9 Selected clinical studies of imiglucerase, velaglucerase, and taliglucerase for the treatment of Type 1 Gaucher disease

Author, Year, Country, Sample Size | ERT | Study Design | Treatment Groups and Dose | Disease Stage/Type | Mean Age at Study Onset (Range) Yrs | Length of Followup (wks) | Hematologic | Liver Size | Spleen Size | Skeletal Pathology | QoL Physical Score | QoL Mental Score
Zimran^44^2011, international n = 15 n = 16 | taliglucerase alfa | Phase III, double-blind, randomized, parallel-group, comparison-dose multinational clinical trial | 30 U/kg eow 60 U/kg eow | symptomatic | 36 (19–74) | 36 | • | • | •
Kishnani41 2009, international; 1. n=33; 2. n=62 | imiglucerase | open-label, randomized, Phase IV, dose frequency trial | 2 treatment groups: 20–60 IU/kg; 1. monthly dose eow; 2. monthly dose every 4 weeks | at least 2 yrs on imiglucerase | age at initial imiglucerase infusion:; 1. 36; (10–74); 2. 42; (11–75) | 104 | • | • | • | • | • | •
Sims42 2008, United States n=33 | imiglucerase | open-label, single cohort prospective study | 60 IU/kg eow | symptomatic | median 43 (12 –70) | 208 | • | • | • | •
de Fost48 2007, Netherlands; 1. n=5; 2. n=6 | imiglucerase | randomized, controlled trial | 2 treatment groups:; 1. 3.45 IU/kg weekly or 7.5 IU/kg eow; 2. 15 IU/kg every 4 weeks | symptomatic | 51 (34–75) | 52 | • | • | •
Grabowski40 1995, United States n=15 | imiglucerase | randomized, double-blind, parallel trial | 60 IU/kg eow | symptomatic | 39 (13–69) | 39 | • | • | •
Elstein39 2011, Israel n = 8 (same study population as Zimran 43 2010) | velaglucerase alfa | extension of Phase I/II open-label study | 60 IU/kg eow tapered to 30 IU/kg eow | symptomatic | 39 (18–62) | 208 | • | • | • | •
Zimran43 2010, Israel (same study population as Elstein 39 2011) Phase I/II: n=11 extension: n=8 | velaglucerase alfa | Phase I/II open-label study | 60 IU/kg eow tapered to 30 IU/kg eow | symptomatic | 41 (18–69) | 39 | • | • | •

Table 10 Selected clinical studies of alglucosidase alfa for the treatment of glycogen storage disease type II (Pompe Disease)

Author, Year, Country, Sample Size | Study Design | Treatment Groups and Dose^*^ | Disease Stage/Type | Mean Age at Study Onset (Range) Yrs | Length of Followup (wks) | Enzyme Level | 6-Min Walk Test | Pulmonary Function | Cardiac Function | Muscle Function | Quality of Life | Survival
Orlikowski72 2011, France n=5 | open-label study in adults | 20 mg/kg eow | juvenile/adult form | 48 (28–62) | 52 | • | | • | | • | •
van der Ploeg73 2010, international; 1. n=60; 2. n=30 | randomized, double-blind, placebo controlled trial | 20 mg/kg eow (Lumizyme) placebo | juvenile/adult form | 45 (16–70) 2) 43 (10–68) | 78 | | • | • | | •
Strothotte74 2010, Germany n=44 | open-label study | 20 mg/kg eow | juvenile/adult form | 49 (21–69) | 52 | • | • | • | | •
Kishnani75 2009, United States n=16 | open-label randomized trial extension to Kishnani, 2006^76^ | 20–40 mg/kg eow | infantile form | mean age at end of study: 3 (2–4) | 60–150 | | | • | • | • | | •
Nicolino77 2009, United States n=21 | open-label study | 20–40 mg/kg eow | infantile and juvenile form | 16 months (4–43) | up to 168 | | | • | • | • | • | •
Levine78 2008, international n=8 | open-label, Phase II trial for children, extension study to Kishnani 2006^76^ | 10–20 mg/kg eow | infantile form | 6 months (3–15) | 52 | | | • | •
McDowell79 2008, international; 1. n=7; 2. n=31 | retrospective study on patients who were in open-label trial for children | 1. patients with arrhythmias; 2. patients without arrhythmias dose not reported | infantile form | 1. median 7 months (6–13); 2. median 8 months; (1–43) | 78 | | | | •
Kishnani76 2006, international n=8 | Phase II, open-label study in children | 10–20 mg/kg weekly or 20 mg/kg eow | infantile form | median age at first treatment: 5 months (3–15) | up to 153 | | | • | • | • | | •

Table 11 Selected clinical studies of laronidase for the treatment of Mucopolysaccharidosis I (MPS I, Hurler, Hurler-Scheie, or Scheie syndrome)

Author, Year, Country, Sample Size | Study Design | Treatment Groups and Dose | Disease Stage/Type | Mean age at study onset (Range) yrs | Length of Follow-up (wks) | Substrate level | Liver Volume | 6-min Walk Test | Range of Motion | Mental Development | Pulmonary Function | Cardiac Symptoms | Sleep Apnea | Visual Acuity | Growth
Clarke82 2009, international n=40 | open-label extension study to Wraith^84^2004 | 100 IU/kg weekly | attenuated | 16 (6–43) | 182 | • | • | • | • | • | • | | • | •
Giugliani49 2009, international; 1. n=8; 2. n=8; 3. n=8; 4. n=9 | dose-optimization trial | 1. 100 IU/kg weekly; 2. 200 IU/kg eow; 3. 200 IU/kg weekly; 4. 300 IU/kg eow | severe (n=10) and attenuated (n=23) | overall: 9 (1–21); 1. 8; (3–17); 2. 9; (5–17); 3. 9; (1–20); 4. 9; (4–21) | 26 | • | • | •
Wraith83 2007, international n=20 | open-label study on children <5 yrs of age | 100–200 IU/kg weekly | severe (n=16) and attenuated (n=4) | 3 (1–5) | 52 | • | • | | | • | | • | • | | •
Wraith84 2004, international laronidase: n=22 placebo: n=23 | Phase III randomized, double-blind, placebo-controlled trial | 100 IU/kg weekly placebo | severe (n=1) and attenuated (n=44) | 16 (7–43) 15 (6–39) | 26 | • | • | • | • | | • | | •
Kakkis85 2001 United States laronidase: n=10 | Phase II trial | 125 IU/kg weekly | intermediate | 5–22 | 52 | • | • | | • | | • | • | | • | •

Table 12 Selected clinical studies of idursulfase (intravenous) for the treatment of Mucopolysaccharidosis II (Hunter Disease)

Author, Year, Country, Sample Size | Study Design | Treatment Groups and Dose | Disease Stage/Type | Mean Age at Study Onset (Range) Yrs | Length of Followup (Wks) | Substrate Level | Spleen Volume | Liver Volume | 6-Min Walk Test | Range of Motion | Pulmonary Function | Cardiac Symptoms | Sleep Apnea | Child Health Disability Index
Okuyama88 2010, Japan n=10 | open-label study in adults | 0.5 mg/kg weekly | attenuated | 30 (21–54) | 52 | • | • | • | • | • | • | • | •
Muenzer87 2011, international n=124 | prospective database study (Hunter Outcome Survey) | 0.5 mg/kg eow | attenuated or severe | 3.8 ± 1.8 | 92 | • | | •
Muenzer86 2011, International n=94 | open-label extension study of Phase II/III randomized double-blind, placebo-controlled trial (Muenzer512006) | 0.5 mg/kg weekly | treatment groups had same distribution baseline disease scores from 2–6 | 5–31 | 104 | | • | • | • | • | • | | | •
Muenzer50 2007, United States idursulfase (intravenous): n=9 placebo: n=3 | Phase I/II, randomized, double-blind, placebo-controlled trial | 1. 0.15 mg/kg eow; 2. 0.5 mg/kg eow; 3. 1.5mg/kg eow; 4. placebo | attenuated | overall: 14 (6–20); 1. 11; (9–14); 2. 20; (20); 3. 8; (6–10); 4. 17; (13–20) | trial: 24 extension: 26 | • | • | • | • | • | • | • | •
Muenzer51 2006, international; 1. idursulfase (intravenous): n=32; 2. idursulfase (intravenous): n=32; 3. placebo: n=32 | Phase II/III, randomized double-blind, placebo-controlled trial | 1. 0.5 mg/kg weekly; 2. 0.5 mg/kg eow; 3. placebo | treatment groups had same distribution baseline disease scores from 2–6 | 1. 15; (6–26); 2. 14; (5–31); 3. 13; (5–29) | 53 | • | • | • | • | • | •

Table 13 Selected clinical studies of galsulfase for the treatment of Mucopolysaccharidosis VI (Maroteaux-Lamy Syndrome)

Author, Year, Country, Sample Size | Study Design | Treatment Groups and Dose | Disease Stage/Type | Mean Age at Study Onset (Range) Yrs | Length of Followup (Wks) | Liver Volume | Stair Climb (3 min) | Walk Test (6 or 12 min) | Range of Motion | Pulmonary Function | Ophthalmologic Evaluation | Sleep Apnea | Growth
Harmatz53 2010, international n=56 | pooled analysis including Phase I/II, II, III studies including extension Phases to 48 weeks | 0.2 mg/kg or 1.0 mg/kg weekly | symptomatic | Phase I/II: 12 (7–16) Phase II: 12 (6–21) Phase III: 14 (5–29) | up to 240 | | | | | • | | | •
Harmatz90 2006, international n=39 | Phase III, randomized, double-blind placebo-controlled trial | 1.0 mg/kg weekly | symptomatic | 14 (5–29) | 48 | | • | •
Harmatz89 2005, international n=10 | open-label study | 1.0 mg/kg weekly | rapidly advancing disease | 13 (6–22) | 48 | • | | • | • | | • | • | •
Harmatz52 2004, international n=7 | Phase I/II randomized, two-dose, double-blind | 0.2 mg/kg weekly n=4 1.0 mg/kg weekly n=3 | entire severity spectrum | 11 (7–16) | 48 | • | • | • | • | • | • | • | •

Harms associated with ERT are reviewed under Guiding Question 1. Those are primarily infusion-related or immune-mediated. Among the clinical studies that were abstracted for Guiding Question 3 (Table 8 through Table 13), there were no reports of adverse events attributed to an ERT product. Long-term adverse sequelae of ERT have not been delineated for most products. Our Key Informants universally indicated the adverse events they have observed were infusion-related or allergic type, not associated with specific actions of the glycoproteins themselves.

#### Fabry Disease

Characteristics of eight studies of agalsidase beta therapy for Fabry disease are summarized in Table 8.^35–37, 47, 68–71^ A total of 288 symptomatic patients were enrolled, counting the 58 patients in the extension study of Germain36 that followed the pivotal trial of Eng.69 Reported ages ranged from 9^37^ to 76^70^ years with the length of follow-up ranging from 20^68, 69^ weeks up to 234^36^ weeks. The ERT dose in all studies ranged from 0.2 mg/kg47, 70 to 1.0 mg/kg every other week (fortnightly). The type of outcomes reported varied, including plasma substrate level, renal function, cerebrovascular disease, pain, growth, and quality of life. Plasma substrate levels and capillary substrate inclusions were reported in the randomized, placebo-controlled pivotal trial.69

#### Gaucher Disease

Table 9 summarizes characteristics of seven studies of ERT (four imiglucerase40–42, 48; two velaglucerase39, 43; one taliglucerase 44) for type I non-CNS Gaucher disease. Two studies were performed in the United States,40, 42 five were international.39, 41, 43, 44, 48, 80 A total of 212 patients (counting patients from the Elstein velaglucerase extension study39) with mild-to-moderate symptoms including anemia, thrombocytopenia, hepatomegaly, splenomegaly, and early bone lesions were enrolled. They ranged in age from as young as 10 years41 to 75 years48 with length of follow-up ranging from 18 weeks39 to 208 weeks.39, 42 Doses ranged from 3.5 IU/kg weekly 48 to 60 IU/kg every other week (fortnightly).39–43 The type of outcomes reported varied, including primarily hematological measures (e.g., anemia, thrombocytopenia), hepatomegaly, splenomegaly, and skeletal abnormalities. Different dose regimens were evaluated in two randomized trials involving imiglucerase.41, 48

#### Glycogen Storage Disease type II (Pompe Disease)

Eight studies of alglucosidase alfa as treatment for glycogen storage disease type II (Pompe disease) are summarized in Table 10.^72–79^ Two are categorized as randomized trials.73, 75 Among the latter, one was the pivotal trial for Lumizyme®.73 All other studies cited in Table 10 involved the other available alglucosidase alfa product, Myozyme®. Two studies were performed in the United States 75, 77 A total of 230 patients, 139 with the juvenile/adult form,72–74 and 91 with infantile Pompe disease75–79, 81 were enrolled, ranging in age from 1 month79 to 70 years.73 Adult or juvenile patients mostly had moderate-to-severe disease manifested by respiratory impairment, myopathy and reduced muscle strength, and impaired mobility.72–74 Patients with infantile Pompe disease had severe manifestations marked by left ventricular hypertrophic cardiomyopathy, profound muscle weakness and hypotonia, and ventilator dependency.64–68, 72 Across all studies, ERT was infused at doses ranging from 10 to 40 mg/kg, weekly or fortnightly. One study evaluated two different dose regimens of alglucosidase alfa.75 The type of outcomes reported varied by type of disease, with cardiac, pulmonary, and muscle function being the most common measures.

#### MPS I (Hurler, Hurler-Scheie, or Scheie syndrome)

Table 11 shows summaries of five clinical studies of α-L-iduronidase (laronidase) therapy that enrolled a total of 148 patients with severe or attenuated forms of MPS I (Hurler, Hurler-Scheie, or Scheie syndrome).49, 82–85 One of the studies was performed solely in the United States. 85 Patients ranged in age from as young as 1 year49, 83 to 43 years.82, 84 Symptoms ranged from mild to severe, including impaired pulmonary function, left-ventricular hypertrophy, hepatomegaly, impaired mobility, impaired growth, sleep apnea, and decreased functional quality of life reflected by the Child Health Assessment Questionnaire/Health Assessment Questionnaire disability index. Doses of laronidase ranged from 100–200 IU/kg weekly to 300 IU/kg fortnightly, with length of follow-up ranging from 26 weeks49, 84 to 182 weeks.82 One study was reported as a randomized, open-label dose-optimization trial using three alternative regimens, shown in Table 11.^49^ The type of outcomes reported varied, most commonly including plasma substrate level, liver volume, 6-minute walk test, and sleep apnea.

#### MPS II (Hunter Disease)

Table 12 shows five studies that enrolled a total of 334 patients (counting patients in the Phase II/III extension study of Muenzer51) with MPS II (Hunter disease).50, 51, 86–88 One was performed in the United States.50 Patients ranged in age from less than 6^87^ to 54^88^ years, with symptoms of MPS II, including hepatosplenomegaly, radiographic evidence of dystosis multiplex, cardiomyopathy, valvular heart disease, joint mobility, and evidence of upper airway obstruction. Two studies were randomized, placebo-controlled trials that evaluated idursulfase (intravenous) in several dose regimens ranging from 0.15 mg/kg weekly50 to 1.5 mg/kg fortnightly.50 The length of follow-up ranged from 24 weeks50 to 53 weeks51 in the initial trials, with one extended to 104 weeks.86 The type of outcomes reported varied, but most commonly included the 6-minute walk test (6MWT) and pulmonary function. The Muenzer 2011 extension study reported the parent- and child-assessed Child Health Assessment Questionnaire Disability Index Score.86 The Hunter Outcome Survey87 is a key prospective database study that reported outcomes in children younger than six years old (mean age 3.8 years), the time at which the MPS II phenotype becomes evident and damage irreversible.

#### MPS VI (Maroteaux-Lamy Disease)

Table 13 shows three international clinical studies of galsulfase in a total of 56 enrolled patients to treat symptomatic or rapidly progressive MPS VI (Maroteaux-Lamy syndrome).52, 89, 90 A fourth article cited in Table 13 is a pooled analysis 53 of all 56 patients included in the three original trials shown there. Symptoms included impaired pulmonary function, impaired walking ability, impaired joint range of motion, skeletal dysplasia, joint stiffness and pain, hepatosplenomegaly, and impaired visual acuity. Patient age ranged from 5^90^ to 29 years.53 Galsulfase was administered at 0.2–1.0 mg/kg weekly, with follow-up ranging from 48 weeks89 to 240 weeks.53 The primary outcome of the 2010 Harmatz study53 was long-term pulmonary function and growth. A 2006 Phase III randomized, double-blind, placebo-controlled trial reported the primary efficacy variable was the distance walked in a 12-minute walk test (12MWT), whereas the secondary efficacy variables were the number of stairs climbed in a 3-minute stair climb (3MSC) and the level of urinary glycosaminoglycan (GAG) excretion.90 The 2004^52^ and 2005^75^ Harmatz studies reported liver volume, 6-minute walk test, joint range of motion and other outcomes.

### Published Registry Studies

Summaries of 11 published registry studies of ERT for Fabry disease, type I Gaucher, MPS II, and MPS VI are shown in Appendix C. These generally reported the same types of outcomes as reported in the clinical studies summarized, previously. However, the actual percentages of outcomes associated with each disease and its treatment may not be as informative as possible, given uncertainty in the real denominators (patient numbers) associated with each registry as participation is voluntary. As noted at a manufacturer-sponsored Web site (www.lysosomallearning.com/support/lsd_sup_registries.asp), no single database or registry exists for all LSDs.

### Unpublished Studies and Ongoing Clinical Studies

For this Technical Brief, the ERT product manufacturers supplied the EPC with compilations of information that included abstracts and posters presented at scientific meetings, as well as product bibliographies and monographs. We cross-indexed the bibliographies we received with published literature identified in our search as well as through NCBI PubMed®. In this exercise, our team did not identify key information, for example novel outcomes or studies, that would extend the general findings we had not already found in the course of this project in published studies, review articles, FDA documents, Key Informant interviews, or manufacturers or advocacy Web sites.

Appendix D shows 29 current clinical studies (Phase I–IV) identified through a search of the ClinicalTrials.gov Web site. These are being performed for all ERT products, with similar endpoints and outcomes as reported for each specific disease as outlined in Table 8 through Table 13 in this Technical Brief. Notably, two studies (NCT0638547, NCT 00852358) are evaluating intrathecal administration of laronidase to treat CNS symptoms of MPS I (MPS I, Hurler, Hurler-Scheie, or Scheie syndrome). Two studies (NCT00920647, NCT 01506141) are evaluating intrathecal administration of idursulfase (intravenous) to treat CNS symptoms of MPS II (Hunter’s disease).

## Guiding Question 4 What are key unresolved or controversial issues with ERT in LSDs?

We sought to address this Guiding Question through integration of information from published clinical studies, narrative review articles, FDA summary documents, and a series of semi-structured interviews with five highly experienced Key Informant physicians and end-users of ERT. The complete discussions are not summarized; rather, we present key clinical concurrences.

### Key Informant Semistructured Telephone Interviews

In the following discussion, unless otherwise stated, the views expressed are those of the authors of this Technical Brief. Views of the Key Informants are specified as such.

The Key Informants universally asserted that CNS neuronopathic aspects of any LSD do not respond to ERT, because the large glycoproteins do not penetrate the blood–brain barrier. One proposed approach to overcome this obstacle is direct intrathecal administration of ERT products. Our literature scan identified two case reports on the intrathecal approach, one in a patient with MPS I,91 the other a patient with MPS VI.92 Intrathecal administration of ERT is the subject of current clinical studies in patients with MPS I and MPS II (see Appendix D).

In our discussions, the Key Informants further indicated that in their experience ERT does not generally reverse established disease-associated damage in patients with any LSD. However, it is not clear what “established” means in terms of type, site, and extent of damage. How this topic could be explored in clinical studies is not clear.

A key point raised in our Key Informant interviews was the importance of timing initiation of ERT prior to or at first appearance of symptoms. We identified published clinical studies that investigated the timing of ERT relative to symptom onset and clinical outcomes for a few LSDs. These include renal function and disease progression in adult patients with Fabry disease treated with agalsidase beta;93 and, avascular necrosis and other manifestations of type I Gaucher disease.94, 95 Several published clinical studies have investigated the impact of early initiation of ERT in infants with Pompe disease.75, 96–100 A key factor in the response of infants with Pompe to ERT is the absence of cross-reacting immunologic material and development of antibodies that may impede response to alglucosidase alfa.101 A study conducted in Germany reported the influence of idursulfase (intravenous) on growth in patients with MPS II, particularly the effect of beginning ERT before the age of 10 years.102

### Patient Advocate Telephone Interviews

Two individuals participated in these anecdotal interviews, a patient affected with an LSD and a caregiver of a patient affected with an LSD. We did not investigate their statements in relationship to the literature. The discussion touched on a variety of issues including clinical outcomes of importance to patients and parents; the importance of “community” in ongoing ERT; information of importance to patients and caregivers; bone marrow transplantation; and, the influence of disease on family members.

The patient with an LSD described several personally important clinical outcomes associated with ERT. These included improved joint range of motion, improved ability to walk, increased energy and feeling of well-being, and independence in daily living. The patient further described how ERT was associated with stabilized cardiac function; improved ability to breathe; improved bone health in terms of reduced pain; and, fewer infections presumably related to immune suppression secondary to the LSD. These types of improvements were of great significance in the patient’s view because they directly affect the quality of life. Quality life with ERT has been studied in patients with type I Gaucher disease,103–105 Fabry disease,106 and MPS I (Hurler, Hurler-Scheie, or Scheie syndrome) disease.107 The patient reported that a shortage-related ERT hiatus resulted in rapid loss of cognitive function and energy, and led to increased bone aching and pain, all of which improved with resumption of ERT. Although cognitive function is not typically affected by the LSD afflicting this patient, a decline was apparent to the patient during the involuntary treatment hiatus. The patient expressed a degree of “guilt” about use of substantial health care resources in times of ERT product shortage. Similar concerns were reported in 2011 among a group of fifty patients with adult type I Gaucher disease in Spain during a 6-month shortage of imiglucerase secondary to viral contamination and manufacturing problems in Europe;108 a similar situation occurred in Australia in 2009.^109^ Shortages of Cerezyme® and Fabrazyme® in the United States were reported by the manufacturer in Fall 2011 (www.gaucherdisease.org/cerezyme_shortage_letter_2011.pdf).

The caregiver we interviewed described the patient under care as full of energy on ERT, social, and no longer readily identifiable (from a distance) as having an LSD. The caregiver further indicated the patient’s doctor has discussed hematopoietic stem-cell transplantation as an option, but cautioned it would not necessarily stabilize cognitive function, carries a high risk of harms, and may not yield any more improvement than ERT. The caregiver also indicated the community aspect of hospital-based therapy as important to a family sense of well-being.