# Background

## Lysosomal Storage Diseases

Lysosomes are generally spherical, subcellular organelles bounded by a single layer membrane within eukaryotic cells. They are ubiquitous structures that contain an array of glycoprotein acid hydrolase enzymes, all of which are synthesized in the endoplasmic reticulum and modified in the Golgi apparatus. Lysosomal enzymes catabolize all major classes of biological macromolecules such as proteins, nucleic acids, glycosphingolipids, mucopolysaccharides, and glycogen, as well as sequestered bacteria, viruses, and other foreign substances that are taken up by phagocytosis into white blood cells and macrophages. Lysosomes are also responsible for autophagy, the gradual turnover of each cell’s own components as they age and become obsolescent. They may be considered the main site of intracellular digestion and housekeeping.

Lysosomal storage diseases (LSDs) comprise a group of unique monogenic autosomal or X-linked diseases that occur secondary to genetic defects (e.g., single nucleotide substitutions, frameshift mutations, gene deletions) that cause total deficiency or reduced activity of specific native enzymes within the lysosomes.1–4 This allows macromolecular compounds that are normally enzymatically catabolized to accumulate within these organelles, expanding them and causing progressive damage in connective tissue, skeletal structure, various organs, and, in some cases, the central nervous system. The damage caused by substrate accumulation results in physical deterioration, functional impairment, and, potentially, death.

Some fifty different LSDs have been identified, broadly divided into categories that are defined by accumulation of a specific macromolecule.1–4 Although each LSD is individually somewhat rare, as a group they have an incidence of about 1 per 7,000 to 8,000 live births, with regional and genetic population variations.4–6 LSDs may be variably expressed as infantile, juvenile, or adult forms. In adult-onset diseases, the pathogenesis is usually slower than in the infantile or juvenile forms, and may include peripheral and CNS symptoms. By contrast, infantile and juvenile forms often involve progressive central nervous system involvement in addition to peripheral symptoms. LSDs also often exhibit significant heterogeneity in ultimate expression, with early or late presentation of symptomatic pathology that may be a function of mutation type and residual enzyme levels. Although specific mutations or types of mutations may be connected to discrete disease effects, genotype-phenotype correlations are often not strong.4

## Therapeutic Measures for Lysosomal Storage Diseases

### Enzyme-Replacement Therapy

Within the United States, the term “enzyme replacement therapy” (ERT) refers to a group of nine commercially available glycoprotein products, each intended to augment or replace the activity of a specific endogenous catabolic enzyme within cellular lysosomes.2, 3, 7–13 All ERT products are administered by intravenous infusion, at dosages typically based on patient body weight, usually weekly or every other week, typically for the life of a patient. The infused enzymes are taken up by cells and transported into lysosomes, where they catabolize the specific macromolecule that has accumulated.

Six ERT products are produced using recombinant DNA methods in Chinese hamster ovary cell cultures (imiglucerase, agalsidase beta, galsulfase, laronidase, alglucosidase alfa [Myozyme® and Lumizyme®]). One (idursulfase) is produced using recombinant DNA methods in a human cell line. One (velaglucerase alfa) is produced using gene-activation technology and a human fibroblast cell culture. One product (taliglucerase) is uniquely produced by recombinant DNA technology in genetically modified carrot cells, rather than in mammalian cell culture.14 Each ERT product is specific for only one LSD. However, three (imiglucerase, velaglucerase alfa, taliglucerase) have been developed to treat type I Gaucher disease, the most common LSD. Two alglucosidase alfa products [Myozyme® and Lumizyme®] are available to treat Pompe disease, although the FDA-approved labels differ as outlined later in this Technical Brief.

### Supportive Care

Prior to the advent of ERT, only supportive care measures were available to manage patients; they are now used in addition to ERT as indicated. These may vary according to the organs and systems that that are affected, and the level of physical impairment.1–3, 15, 16 Supportive care is not curative, and once a certain degree of tissue or organ damage develops, it may become difficult or impossible to reverse, even with ERT. Therefore, early diagnosis and timely treatment is crucial to optimal management of LSDs. For example, patients with Type 1 Gaucher disease, the most common LSD, may develop visceral problems (e.g., hepatomegaly, splenomegaly), anemia, thrombocytopenia, lung disease, severe bone pain (acute or chronic), avascular necrosis, and have growth impairment and pubertal delay.17 Supportive care prior to the development of specific ERT may have comprised combinations of therapies that could include blood transfusion, bed rest, analgesia, anti-inflammatory agents, hyperbaric oxygen, and surgery (splenectomy, orthopedic procedures). In the age of ERT, however, many of these are no longer used nor recommended (e.g., splenectomy).

### Substrate Reduction Therapy

Substrate reduction therapy (SRT) has been proposed as another potential strategy to treat LSDs.18–27 SRT refers to the inhibition of synthesis of macromolecules that accumulate in the lysosomes of tissues and organs of patients with LSDs. The effectiveness of SRT depends on the existence of residual catabolic enzyme activity specific to the substance and disease for which it is used. Thus, if the rate of synthesis of a macromolecule is reduced, residual enzyme levels may be sufficient to degrade it, thereby reducing accumulation.

One SRT product—miglustat—has received FDA marketing approval for treatment of adult patients with mild to moderate type I Gaucher disease for whom ERT is not a therapeutic option.22, 25 This agent is not an ERT product and will not be considered further in this Technical Brief.

### Allogeneic Hematopoietic Stem-Cell Transplantation (HSCT)

Allogeneic HSCT has been investigated as a curative option for selected patients with several of the LSDs considered in this Technical Brief. The success of HSCT is variable, depending on the LSD and the underlying condition of the patient. A comprehensive comparative effectiveness review (CER) is available from AHRQ that assesses the body of evidence on the use of allogeneic HSCT to treat all the LSDs considered in this Technical Brief.28

The AHRQ CER concludes that overall there appears to be a favorable risk-benefit profile for the treatment of MPS I with HSCT for severe cases with stable cardiopulmonary function, if the disease is diagnosed at 2 years of age or younger and the disability quotient (DQ) is 70 or greater. There also appears to be a favorable risk-benefit profile for the treatment of MPS I with HSCT for rare attenuated cases in which the diagnosis is made at older than 2 years of age and the DQ is 70 or greater.29 Likewise, overall there appears to be a favorable risk-benefit profile for the treatment of MPS VI with HSCT when enzyme replacement is not available or after failure of enzyme replacement. ERT may be used in conjunction with allogeneic HSCT, or to prepare patients with an LSD for the procedure. Supplemental treatment may include physical therapy, occupational therapy, and treatment-related surgery and medications.30

## Technical Brief Objective

The objective of this Technical Brief is to provide an overview of FDA-approved ERT for the treatment of six lysosomal storage diseases shown in Table 1. Four Guiding Questions (following) address the clinical indications for each ERT, potential benefits and harms associated with each ERT product, and dosing and administration details of each ERT. An electronic scan of the literature provides a picture of published evidence on clinical use of these agents for each LSD. This Technical Brief also discusses unresolved or controversial issues surrounding the use of ERT to treat lysosomal storage diseases, based on the literature and information obtained through semi-structured, one-on-one telephone interviews with Key Informants.

Table 1 Lysosomal storage diseases with U.S. Food and Drug Administration (FDA)-approved enzyme-replacement therapy

Disease | Deficient Enzyme (FDA-Approved Product) | Pathological Lysosomal Macromolecule | Clinical Description and Expression
Fabry Disease | α-galactosidase A (Fabrazyme®) | glycosphingolipids, predominantly globotriaosylceramide and galabiosylceramide | Fabry disease is an X-linked disorder with an onset of symptoms and severity of symptoms that vary widely among patients. Males may exhibit symptoms in childhood or adolescence, or remain asymptomatic into adulthood. Females may have no early symptoms and only mild symptoms in later years or have symptoms as severe as affected males. Early symptoms include a whorl-like pattern visible in the cornea, skin lesions, pain in the extremities, decreased ability to sweat, gastrointestinal symptoms such as chronic abdominal pain and diarrhea, followed by slow decline in kidney function. Cardiomyopathy, arrhythmia, and stroke may occur. Fabry pain may present as chronic pain (acroparesthesia, which is near-constant tingling or numbness, nagging, burning pain in the hands and feet), or acute pain crises, which are episodes of excruciating pain, usually in the extremities and radiating inward, and often accompanied by fever and elevated erythrocyte sedimentation rate (ESR). Both are common early signs of Fabry disease, especially in boys. Prior to the development of dialysis, HSCT, or ERT, life expectancy was 40–50 years, with cause of death usually due to a decline in kidney function or to cardiovascular disease.
Type 1 Gaucher disease | glucocerebrosidase (Cerezyme®, VPRIV™, Elelyso™) | glucosylceramide | Type 1 Gaucher disease is the most common lysosomal storage disease. The onset of symptoms is variable, from early childhood to late adulthood. The majority of patients with Gaucher disease have symptoms in childhood, although the age of onset can vary markedly. Patients presenting in early childhood have a more severe course of the disease compared to those presenting later in life. Signs and symptoms include anemia, hepatosplenomegaly, skeletal diseases and very rarely, lung or liver impairment. Growth deficiencies and pubertal delay may be common. The clinical course, disease progression, and severity among the different organ systems vary markedly among cases. Type 1 Gaucher disease is typically defined by a lack of CNS involvement. Life expectancy varies widely, depending on the severity of symptoms, and can extend to near normal expectancy.
Glycogen Storage Disease type II (Pompe disease) | acid alpha-glucosidase (Myozyme®, Lumizyme®) | glycogen | Pompe disease is often grouped into early and late onset forms, although in reality a spectrum of disease may occur with differing age of onset and rapidity of progression. Symptoms appear in the first few months of life in the infantile form of the disease. Many patients with Pompe disease with late onset have symptoms in early childhood, sometimes even in infancy. There are feeding problems, poor weight gain, muscle weakness, floppiness, head lag, respiratory difficulties, and an enlarged heart. Life expectancy is less than 1 year, with cause of death usually from cardiorespiratory failure or respiratory infection. Onset of symptoms in the late onset form of the disease ranges from the first decade to the sixth decade of life. Severity of symptoms varies markedly among patients. Patients experience muscle weakness, progressive respiratory weakness, and either no or mild cardiac insufficiencies. Prior to the availability of ERT, survival depended on the severity and rate of disease progression, with cause of death usually due to respiratory failure.
MPS I (Hurler, Hurler-Scheie, or Scheie syndrome) | alpha-L-iduronidase (Aldurazyme®) | glycosaminoglycans dermatan sulfate and heparan sulfate | MPS I comprises a wide spectrum of severity, with a wide range of symptoms that differ from patient to patient with regard to age of onset and severity. Individuals may be categorized anywhere from severe to attenuated (less severe). The classifications Hurler, Hurler-Scheie, and Scheie are now considered to be oversimplifications that do not adequately reflect the tremendous variation in symptoms, presentation and progression. The term “attenuated” rather than “mild” is used to describe the less severe individuals because of effects of the disease on a less severe individuals are too significant to be considered mild. Though the symptoms manifest in a continuous spectrum among patients, for clinical purposes, they often are categorized into the following three groups: MPS IH (Hurler) is the most severe form with symptoms presenting within the first 12 months of age. Symptoms may include respiratory insufficiency, hearing loss, joint movement restriction, enlargement of the heart, spleen, and liver, and progressive cognitive deterioration, coarse facial features, growth deficits, heart disease, clouded corneas, and inguinal and umbilical hernias. Prior to the availability of HSCT, life expectancy was less than 12 years, with cause of death most commonly due to obstructive airway disease, upper respiratory infections, or cardiac complications. MPS IH/S (Hurler-Scheie) is an intermediate form of the disease with symptoms presenting usually from 3–6 years of age. Symptoms and signs may include growth deficiencies, deafness, coarse facial features, clouded corneas, inguinal and umbilical hernia, and heart disease. Life expectancy for Hurler-Scheie is late teens to early twenties. MPS IS (Scheie) is the attenuated form of the disease with symptoms presenting from 5–12 years of age. Symptoms may include stiff joints, clouded corneas, cardiac valve disease, normal intelligence or mild learning disabilities. Life expectancy extends into adulthood, though significant morbidity occurs.
MPS II (Hunter disease) | iduronate sulfatase (Elaprase®) | glycosaminoglycans dermatan sulfate and heparan sulfate | MPS II is an X-linked disorder. Although most patients are male, females can also be affected. However, for clinical purposes, women are almost never affected. The clinical symptoms of MPS II are highly variable, differing among patients in which symptoms develop, age of onset and severity. MPS II exhibits a continuous spectrum of disease, ranging from severe on one end to an attenuated form on the other, with a range in between. The more severe form has CNS involvement with symptoms presenting between 2 and 5 years of age. Symptoms may include short stature, organomegaly, joint stiffness, hearing loss, progressive cognitive deterioration, behavioral disorders, progressive airway disease, and cardiac disease. Prior to the advent of ERT, life expectancy ranged from 10–20 years. Death usually results from cardiorespiratory disease due to progressive obstructive and restrictive lung disease along with cardiac valvular disease. Patients with the attenuated form of the disease may not be diagnosed until school-age, adolescence, or adulthood. The physical symptoms may include the same as the severe form, but are milder in nature. Usually the CNS is not involved. Prior to ERT, life expectancy was 20–60 years.
MPS VI (Maroteaux-Lamy syndrome) | arylsulfatase B (Naglazyme™) | dermatan sulfate glycosaminoglycan | As with the other forms of MPS, the following vary among patients: which symptoms develop, age of onset of symptoms, and severity of symptoms. Growth and development can be normal the first few years of life, but appear to stop around age 6. Linear growth is severely limited in MPS VI, and these patients without ERT have marked short stature, and the effects of ERT on growth are not yet completely understood. The clinical characteristics are much like MPS I, except with a later onset and a slower progression of symptoms. In comparison to MPS I, skeletal deformities tend to be more prominent, joint symptoms are characterized by hypermobility rather than stiffness, and cognitive involvement is very rare. Psychomotor skills are affected by the physical and visual impairments of the disease. Prior to ERT, life expectancy depended on severity of symptoms, ranging from less than 20 years to later adulthood, with cause of death usually from cardiorespiratory disease due to progressive obstructive and restrictive lung disease along with cardiac valvular disease.

* Textbook Sources:

Beutler E, Grabowski GA. Gaucher disease. In: Scriver CR, Beaudet AL, Sly WS, et al. (eds.): The Metabolic and Molecular Bases of Inherited Disease (vol. 3, 8^th^ ed.). New York: McGraw-Hill, 2001;3635–68.

Kishnani PS, Chen YT. Defects in Metabolism of Carbohydrates. In: Kleigman RM, Behrman RE, Jenson HB, Stanton B, ed. Nelson Textbook of Pediatrics. 18th ed. Philadelphia, Pa: Saunders Elsevier; 2007; chap 87.

McGovern MM, Desnick RJ. Lysosomal Storage Diseases. In: Goldman L, Ausiello DA, ed. Goldman Cecil Medicine, 23^rd^ ed. Saunders Elsevier; 2007; chap 223.

McGovern MM, Desnick RJ. Lipidoses. In: Kleigman RM, Behrman RE, Jenson HB, Stanton B, ed. Nelson Textbook of Pediatrics. 18th ed. Philadelphia, Pa: Saunders Elsevier; 2007b; chap 86.

Spranger J. Mucopolysaccharidoses. In: Kleigman RM, Behrman RE, Jenson HB, et al., ed. Nelson Textbook of Pediatrics. 18th ed. Philadelphia, Pa: Saunders Elsevier; 2007; chap 88.

Tinkle BT, Leslie N. Glycogen Storage Disease Type II (Pompe Disease). In: Pagon RA, Bird TC, Dolan CR, et al., In: Pagon RA, Bird TC, Dolan CR, et al., editors. GeneReviews [Internet]. Seattle (WA): University of Washington, Seattle; 1993–2007 Aug 31 [updated 2010 Aug 12].

## Guiding Questions

1. What FDA-approved enzyme-replacement therapy (ERT) products are available for lysosomal storage diseases (LSDs)?
  a. What are the clinical indications for each FDA-approved ERT product?
  b. What are the potential benefits of ERT for LSDs?
  c. What are the potential safety issues and harms with ERT?
2. What is the context in which each FDA-approved ERT product is used?
  a. What are the FDA-approved dose regimens for each ERT product?
  b. Where and by whom is ERT administered?
  c. What adjunct treatments are used with each FDA-approved ERT product?
3. What published and unpublished studies have reported on the use and safety of this intervention?
  a. Type of ERT
  b. Indication/patient inclusion criteria
  c. Study design/size
  d. Comparator used in comparative studies
  e. Concurrent/prior treatments
  f. Length of followup
  g. Outcomes measured
4. What are key unresolved or controversial issues with ERT in LSDs?