# Resource Bibliography

## Fabry Disease

1 Agalsidase beta (Fabrazyme) for Fabry disease. Med Lett Drugs Ther. Sep. 15. 2003;45(1165):74-5. [pmid: 12968124].
2 Agalsidase evaluation: A case in point. Prescrire International. 2003;12(67):162.
3 Agalsidase beta slows the progression of advanced Fabry’s disease. Nature Clinical Practice Nephrology. 2007;3(4):181.
4 Aaron JA, Ansani NT. Agalsidase beta: Enzyme replacement therapy for fabry disease. P and T. 2005;30(4):222-4.
5 Abaterusso C, De Biase V, Salviati A, et al. Unusual renal presentation of Fabry disease in a female patient. Nat Rev Nephrol. Jun. 2009;5(6):349-54. [pmid: 19399018].
6 Banikazemi M, Bultas J, Waldek S, et al. Agalsidase-beta therapy for advanced Fabry disease: a randomized trial. Ann Intern Med. Jan. 16. 2007;146(2):77-86. [pmid: 17179052].
7 Banikazemi M, Desnick RJ. Does enzyme replacement therapy improve symptoms of Fabry disease in patients undergoing dialysis?. Nat Clin Pract Nephrol. Feb. 2006;2(2):72-3. [pmid: 16932395].
8 Banikazemi M, Ullman T, Desnick RJ. Gastrointestinal manifestations of Fabry disease: clinical response to enzyme replacement therapy. Mol Genet Metab. Aug. 2005;85(4):255-9. [pmid: 15939645].
9 Barbey F, Hayoz D, Widmer U, et al. Efficacy of enzyme replacement therapy in Fabry disease. Curr Med Chem Cardiovasc Hematol Agents. Oct. 2004;2(4):277-86. [pmid: 15320778].
10 Barbey F, Lidove O, Schwarting A. Fabry nephropathy: 5 years of enzyme replacement therapy - A short review. NDT Plus. 2008;1(1):11-9.
11 Barngrover D. Fabrazyme–recombinant protein treatment for Fabry’s disease. J Biotechnol. May. 23. 2002;95(3):280-2. [pmid: 12080957].
12 Beer M, Weidemann F, Breunig F, et al. Impact of Enzyme Replacement Therapy on Cardiac Morphology and Function and Late Enhancement in Fabry’s Cardiomyopathy. American Journal of Cardiology. 2006;97(10):1515-8. [pmid: 16679096].
13 Bengtsson BA, Johansson JO, Hollak C, et al. Enzyme replacement in Anderson-Fabry disease. Lancet. Jan. 25. 2003;361(9354):352. [pmid: 12559898].
14 Bouwman MG, Hollak CE, van den Bergh Weerman MA, et al. Analysis of placental tissue in Fabry disease with and without enzyme replacement therapy. Placenta. Apr. 2010;31(4):344-6. [pmid: 20189642].
15 Breunig F, Wanner C. Enzyme replacement therapy for Fabry disease: Proving the clinical benefit. Nephrology Dialysis Transplantation. 2003;18(1):7-9.
16 Breunig F, Wanner C. Update on Fabry disease: Kidney involvement, renal progression and enzyme replacement therapy. Journal of Nephrology. 2008;21(1):32-7. [pmid: 18264934].
17 Caballero L, Climent V, Hernandez-Romero D, et al. Enzyme replacement therapy in Fabry disease: influence on cardiac manifestations. Curr Med Chem. 2010;17(16):1679-89. [pmid: 20345350].
18 Cho ME, Kopp JB. Fabry disease in the era of enzyme replacement therapy: A renal perspective. Pediatric Nephrology. 2004;19(6):583-93. [pmid: 15064943].
19 Choi JH, Cho YM, Suh KS, et al. Short-term efficacy of enzyme replacement therapy in Korean patients with Fabry disease. J Korean Med Sci. Apr. 2008;23(2):243-50. [pmid: 18437007].
20 Clarke JT, Iwanochko RM. Enzyme replacement therapy of Fabry disease. Mol Neurobiol. Aug. 2005;32(1):43-50. [pmid: 16077182].
21 Collin C, Briet M, Tran TC, et al. Long-term changes in arterial structure and function and left ventricular geometry after enzyme replacement therapy in patients affected with Fabry disease. Eur J Cardiovasc Prev Rehabil. 2011. Mar. 4. [pmid: 21450622].
22 Collin C, Briet M, Tran TC, et al. Long-term changes in arterial structure and function and left ventricular geometry after enzyme replacement therapy in patients affected with Fabry disease. Eur J Prev Cardiolog. Feb. 2012;19(1):43-54. [pmid: 21450622].
23 Connock M, Juarez-Garcia A, Frew E, et al. A systematic review of the clinical effectiveness and cost-effectiveness of enzyme replacement therapies for Fabry’s disease and mucopolysaccharidosis type 1. Health Technol Assess. Jun. 2006;10(20):iii-iv. ix. 113. [pmid: 16729919].
24 De Schoenmakere G, Chauveau D, Grunfeld JP. Enzyme replacement therapy in Anderson-Fabry’s disease: beneficial clinical effect on vital organ function. Nephrol Dial Transplant. Jan. 2003;18(1):33-5. [pmid: 12480957].
25 Deegan PB. Fabry disease, enzyme replacement therapy and the significance of antibody responses. J Inherit Metab Dis. Mar. 2012;35(2):227-43. [pmid: 22037707].
26 del Toro N, Milan JA, Palma A. Enzyme replacement in the treatment of Fabry’s disease. Is there a point-of-no-return?. Nephrol Dial Transplant. Apr. 2004;19(4):1018. [pmid: 15031378].
27 Desnick RJ. Enzyme replacement therapy for Fabry disease: lessons from two alpha-galactosidase A orphan products and one FDA approval. Expert Opin Biol Ther. Jul. 2004;4(7):1167-76. [pmid: 15268683].
28 Desnick RJ, Banikazemi M. Fabry disease: clinical spectrum and evidence-based enzyme replacement therapy. Nephrol Ther. Jan. 2006;2(Suppl 2):S172-85. [pmid: 17373219].
29 Desnick RJ, Brady R, Barranger J, et al. Fabry disease, an under-recognized multisystemic disorder: expert recommendations for diagnosis, management, and enzyme replacement therapy. Ann Intern Med. Feb. 18. 2003;138(4):338-46. [pmid: 12585833].
30 El Dib RP, Pastores GM. Enzyme replacement therapy for Anderson-Fabry disease. Cochrane Database Syst Rev. 2010;5:CD006663. [pmid: 20464743].
31 Eng CM, Germain DP, Banikazemi M, et al. Fabry disease: guidelines for the evaluation and management of multi-organ system involvement. Genet Med. Sep. 2006;8(9):539-48. [pmid: 16980809].
32 Eto Y, Ohashi T, Utsunomiya Y, et al. Enzyme replacement therapy in Japanese Fabry disease patients: the results of a phase 2 bridging study. J Inherit Metab Dis. 2005;28(4):575-83. [pmid: 15902561].
33 Faggiano A, Severino R, Ramundo V, et al. Thyroid function in Fabry disease before and after enzyme replacement therapy. Minerva Endocrinologica. 2011;36(1):1-5. [pmid: 21460782].
34 Feldt-Rasmussen U. Fabry disease and early stroke. Stroke Research and Treatment. 2011.
35 Fervenza FC, Torra R, Warnock DG. Safety and efficacy of enzyme replacement therapy in the nephropathy of Fabry disease. Biologics. Dec. 2008;2(4):823-43. [pmid: 19707461].
36 Germain DP, Bruneval P, Tran TC, et al. Uneventful pregnancy outcome after enzyme replacement therapy with agalsidase beta in a heterozygous female with Fabry disease: A case report. Eur J Med Genet. Mar–Apr. 2010;53(2):111-2. [pmid: 20045092].
37 Germain DP, Waldek S, Banikazemi M, et al. Sustained, long-term renal stabilization after 54 months of agalsidase beta therapy in patients with Fabry disease. J Am Soc Nephrol. May. 2007;18(5):1547-57. [pmid: 17409312].
38 Guffon N, Fouilhoux A. Clinical benefit in Fabry patients given enzyme replacement therapy–a case series. J Inherit Metab Dis. 2004;27(2):221-7. [pmid: 15159653].
39 Hesselgrave B. Diagnostic challenges and new therapies for rare lysosomal storage diseases. Case Manager. Nov–Dec. 2003;14(6):48-52. [pmid: 14618149].
40 Hilz MJ, Brys M, Marthol H, et al. Enzyme replacement therapy improves function of C-, Adelta-, and Abeta-nerve fibers in Fabry neuropathy. Neurology. Apr. 13. 2004;62(7):1066-72. [pmid: 15079003].
41 Hilz MJ, Koehn J, Kolodny EH, et al. Metronomic breathing shows altered parasympathetic baroreflex function in untreated Fabry patients and baroreflex improvement after enzyme replacement therapy. J Hypertens. Dec. 2011;29(12):2387-94. [pmid: 21970939].
42 Hilz MJ, Marthol H, Schwab S, et al. Enzyme replacement therapy improves cardiovascular responses to orthostatic challenge in Fabry patients. J Hypertens. Jul. 2010;28(7):1438-48. [pmid: 20125036].
43 Hirashio S, Taguchi T, Naito T, et al. Renal histology before and after effective enzyme replacement therapy in a patient with classical Fabry’s disease. Clin Nephrol. May. 2009;71(5):550-6. [pmid: 19473616].
44 Hollak CE, Linthorst GE. Immune response to enzyme replacement therapy in Fabry disease: impact on clinical outcome?. Mol Genet Metab. Jan. 2009;96(1):1-3. [pmid: 19062323].
45 Hollak CEM, Aerts JMFG, Ayme S, et al. Limitations of drug registries to evaluate orphan medicinal products for the treatment of lysosomal storage disorders. Orphanet Journal of Rare Diseases. 2011;6(1).
46 Hopkin RJ, Bissler J, Grabowski GA. Comparative evaluation of alpha-galactosidase A infusions for treatment of Fabry disease. Genet Med. May–Jun. 2003;5(3):144-53. [pmid: 12792421].
47 Imbriaco M, Pisani A, Spinelli L, et al. Effects of enzyme-replacement therapy in patients with Anderson-Fabry disease: a prospective long-term cardiac magnetic resonance imaging study. Heart. Jul. 2009;95(13):1103-7. [pmid: 19372091].
48 Kalliokoski RJ, Kantola I, Kalliokoski KK, et al. The effect of 12-month enzyme replacement therapy on myocardial perfusion in patients with Fabry disease. J Inherit Metab Dis. Feb. 2006;29(1):112-8. [pmid: 16601877].
49 Kampmann C, Wiethoff CM, Perrot A, et al. The heart in Anderson Fabry disease. Z Kardiol. Oct. 2002;91(10):786-95. [pmid: 12395219].
50 Kato T, Nishimura K, Ichikawa Y. Deceased renal transplantation in patient with Fabry’s disease maintained by enzyme replacement therapy. Int J Urol. Jul. 2009;16(7):650. [pmid: 19659805].
51 Keating GM, Simpson D. Spotlight on agalsidase beta in Fabry disease. BioDrugs. 2007;21(4):269-71. [pmid: 17628124].
52 Keating GM, Simpson D. Agalsidase Beta: a review of its use in the management of Fabry disease. Drugs. 2007;67(3):435-55. [pmid: 17335299].
53 Kim W, Pyeritz RE, Bernhardt BA, et al. Pulmonary manifestations of Fabry disease and positive response to enzyme replacement therapy. Am J Med Genet A. Feb. 15. 2007;143(4):377-81. [pmid: 17256799].
54 Kovacevic-Preradovic T, Zuber M, Attenhofer Jost CH, et al. Anderson-Fabry disease: long-term echocardiographic follow-up under enzyme replacement therapy. Eur J Echocardiogr. Nov. 2008;9(6):729-35. [pmid: 18490303].
55 Lidove O, Joly D, Barbey F, et al. Clinical results of enzyme replacement therapy in Fabry disease: a comprehensive review of literature. Int J Clin Pract. Feb. 2007;61(2):293-302. [pmid: 17263716].
56 Lidove O, West ML, Pintos-Morell G, et al. Effects of enzyme replacement therapy in Fabry disease–a comprehensive review of the medical literature. Genet Med. Nov. 2010;12(11):668-79. [pmid: 20962662].
57 Lim-Melia ER, Kronn DF. Current enzyme replacement therapy for the treatment of lysosomal storage diseases. Pediatr Ann. Aug. 2009;38(8):448-55. [pmid: 19725195].
58 Linthorst GE, Aerts JM. Letter concerning “Enzyme replacement therapy in a patient with Fabry disease and the development of IgE antibodies against agalsidase beta but not agalsidase alpha”, by Tanaka et al. J Inherit Metab Dis. Feb. 2011;34(1):237-8. [pmid: 20938807].
59 Linthorst GE, Vedder AC, Ormel EE, et al. Home treatment for Fabry disease: practice guidelines based on 3 years experience in The Netherlands. Nephrol Dial Transplant. Feb. 2006;21(2):355-60. [pmid: 16249196].
60 Lubanda JC, Anijalg E, Bzduch V, et al. Evaluation of a low dose, after a standard therapeutic dose, of agalsidase beta during enzyme replacement therapy in patients with Fabry disease. Genet Med. Apr. 2009;11(4):256-64. [pmid: 19265719].
61 Mehta A. Fabry disease–whom to treat and when. Clin Ther. 2008;30(Suppl B):S43-4. [pmid: 18395136].
62 Mehta A, Beck M, Kampmann C, et al. Enzyme replacement therapy in Fabry disease: comparison of agalsidase alfa and agalsidase beta. Mol Genet Metab. Sep–Oct. 2008;95(1–2):114-5. [pmid: 18701330].
63 Messalli G, Imbriaco M, Avitabile G, et al. Role of cardiac MRI in evaluating patients with Anderson-Fabry disease: assessing cardiac effects of long-term enzyme replacement therapy. Radiol Med. 2011. Jul. 9. [pmid: 21744250].
64 Messalli G, Imbriaco M, Avitabile G, et al. Role of cardiac MRI in evaluating patients with Anderson-Fabry disease: assessing cardiac effects of long-term enzyme replacement therapy. Radiol Med. Feb. 2012;117(1):19-28. [pmid: 21744250].
65 Mignani R, Cagnoli L. Enzyme replacement therapy in Fabry’s disease: recent advances and clinical applications. J Nephrol. May–Jun. 2004;17(3):354-63. [pmid: 15365954].
66 Mignani R, Feriozzi S, Pisani A, et al. Agalsidase therapy in patients with Fabry disease on renal replacement therapy: a nationwide study in Italy. Nephrol Dial Transplant. May. 2008;23(5):1628-35. [pmid: 18057066].
67 Mignani R, Panichi V, Giudicissi A, et al. Enzyme replacement therapy with agalsidase beta in kidney transplant patients with Fabry disease: a pilot study. Kidney Int. Apr. 2004;65(4):1381-5. [pmid: 15086478].
68 Mills K, Vellodi A, Morris P, et al. Monitoring the clinical and biochemical response to enzyme replacement therapy in three children with Fabry disease. Eur J Pediatr. Oct. 2004;163(10):595-603. [pmid: 15243806].
69 Motabar O, Sidransky E, Goldin E, et al. Fabry disease - current treatment and new drug development. Current Chemical Genomics. 2010;4(1):50-6. [pmid: 21127742].
70 Ortiz A, Oliveira JP, Wanner C, et al. Recommendations and guidelines for the diagnosis and treatment of Fabry nephropathy in adults. Nature Clinical Practice Nephrology. 2008;4(6):327-36.
71 Phadke SR, Mandal K, Girisha KM. Fabry disease: a treatable lysosomal storage disorder. Natl Med J India. Jan–Feb. 2009;22(1):20-2. [pmid: 19761154].
72 Pintos-Morell G, Beck M. Fabry disease in children and the effects of enzyme replacement treatment. Eur J Pediatr. Nov. 2009;168(11):1355-63. [pmid: 19242721].
73 Politei JM. Treatment with agalsidase beta during pregnancy in Fabry disease. J Obstet Gynaecol Res. Apr. 2010;36(2):428-9. [pmid: 20492401].
74 Prinz C, Farr M, Hering D, et al. Reduction in ECG abnormalities and improvement of regional left ventricular function in a patient with Fabry’s disease during enzyme-replacement therapy. Clin Res Cardiol. Jan. 2010;99(1):53-5. [pmid: 19774328].
75 Rozenfeld P, Neumann PM. Treatment of fabry disease: Current and emerging strategies. Current Pharmaceutical Biotechnology. 2011;12(6):916-22. [pmid: 21235448].
76 Schaefer RM, Tylki-Szymanska A, Hilz MJ. Enzyme replacement therapy for Fabry disease: a systematic review of available evidence. Drugs. Nov. 12. 2009;69(16):2179-205. [pmid: 19852524].
77 Schiffmann R. Enzyme replacement in Fabry disease: the essence is in the kidney. Ann Intern Med. Jan. 16. 2007;146(2):142-4. [pmid: 17179053].
78 Schiffmann R. Agalsidase treatment for Fabry disease: uses and rivalries. Genet Med. Nov. 2010;12(11):684-5. [pmid: 20975568].
79 Sheppard MN, Cane P, Florio R, et al. A detailed pathologic examination of heart tissue from three older patients with Anderson-Fabry disease on enzyme replacement therapy. Cardiovasc Pathol. Sep–Oct. 2010;19(5):293-301. [pmid: 19631563].
80 Siamopoulos KC. Fabry disease: kidney involvement and enzyme replacement therapy. Kidney Int. Feb. 2004;65(2):744-53. [pmid: 14717955].
81 Sirrs S, Clarke JT, Bichet DG, et al. Baseline characteristics of patients enrolled in the Canadian Fabry Disease Initiative. Mol Genet Metab. Apr. 2010;99(4):367-73. [pmid: 20022777].
82 Spinelli L, Pisani A, Sabbatini M, et al. Enzyme replacement therapy with agalsidase beta improves cardiac involvement in Fabry’s disease. Clin Genet. Aug. 2004;66(2):158-65. [pmid: 15253767].
83 Suzuki K, Miura N, Kitagawa W, et al. Progressive renal failure despite long-term biweekly enzyme replacement therapy in a patient with Fabry disease secondary to a new alpha-galactosidase mutation of Leu311Arg (L311R). Clin Exp Nephrol. 2011. Jul. 15. [pmid: 21755431].
84 Tahir H, Jackson LL, Warnock DG. Antiproteinuric therapy and fabry nephropathy: sustained reduction of proteinuria in patients receiving enzyme replacement therapy with agalsidase-beta. J Am Soc Nephrol. Sep. 2007;18(9):2609-17. [pmid: 17656478].
85 Tanaka A, Takeda T, Hoshina T, et al. Enzyme replacement therapy in a patient with Fabry disease and the development of IgE antibodies against agalsidase beta but not agalsidase alpha. J Inherit Metab Dis. 2010. Jun. 22. [pmid: 20567910].
86 Tesmoingt C, Lidove O, Reberga A, et al. Enzyme therapy in Fabry disease: severe adverse events associated with anti-agalsidase cross-reactive IgG antibodies. Br J Clin Pharmacol. Nov. 2009;68(5):765-9. [pmid: 19917001].
87 Thurberg BL, Phelps R, Granter S, et al. Fabrazyme clears globotriaosylceramide from the skin of fabry patients abstract. 2003. http://www.mrw.interscience.wiley.com/cochrane/clcentral/articles/044/CN-00593044/frame.html.
88 Uceyler N, He L, Schonfeld D, et al. Small fibers in Fabry disease: Baseline and follow-up data under enzyme replacement therapy. Journal of the Peripheral Nervous System. 2011;16(4):304-14. [pmid: 22176145].
89 van Breemen MJ, Rombach SM, Dekker N, et al. Reduction of elevated plasma globotriaosylsphingosine in patients with classic Fabry disease following enzyme replacement therapy. Biochim Biophys Acta. Jan. 2011;1812(1):70-6. [pmid: 20851180].
90 Vedder AC, Breunig F, Donker-Koopman WE, et al. Treatment of Fabry disease with different dosing regimens of agalsidase: effects on antibody formation and GL-3. Mol Genet Metab. Jul. 2008;94(3):319-25. [pmid: 18424138].
91 Vedder AC, Linthorst GE, Houge G, et al. Treatment of Fabry disease: outcome of a comparative trial with agalsidase alfa or beta at a dose of 0.2 mg/kg. PLoS One. 2007;2(7):e598. [pmid: 17622343].
92 Wang RY, Abe JT, Cohen AH, et al. Enzyme replacement therapy stabilizes obstructive pulmonary Fabry disease associated with respiratory globotriaosylceramide storage. J Inherit Metab Dis. Dec. 2008;31(Suppl 2):369-74. [pmid: 18937048].
93 Warnock DG, Daina E, Remuzzi G, et al. Enzyme replacement therapy and fabry nephropathy. Clinical Journal of the American Society of Nephrology. 2010;5(2):371-8. [pmid: 20007680].
94 Warnock DG, Ortiz A, Mauer M, et al. Renal outcomes of agalsidase beta treatment for Fabry disease: role of proteinuria and timing of treatment initiation. Nephrol Dial Transplant. 2011. Jul. 29. [pmid: 21804088].
95 Warnock DG, Ortiz A, Mauer M, et al. Renal outcomes of agalsidase beta treatment for Fabry disease: role of proteinuria and timing of treatment initiation. Nephrol Dial Transplant. Mar. 2012;27(3):1042-9. [pmid: 21804088].
96 Watt T, Burlina AP, Cazzorla C, et al. Agalsidase beta treatment is associated with improved quality of life in patients with Fabry disease: findings from the Fabry Registry. Genet Med. Nov. 2010;12(11):703-12. [pmid: 20885332].
97 Weidemann F, Breunig F, Beer M, et al. Improvement of cardiac function during enzyme replacement therapy in patients with Fabry disease: a prospective strain rate imaging study. Circulation. Sep. 16. 2003;108(11):1299-301. [pmid: 12952834].
98 Wilcox WR, Banikazemi M, Guffon N, et al. Long-term safety and efficacy of enzyme replacement therapy for Fabry disease. Am J Hum Genet. Jul. 2004;75(1):65-74. [pmid: 15154115].
99 Wilcox WR, Linthorst GE, Germain DP, et al. Anti-alpha-galactosidase A antibody response to agalsidase beta treatment: data from the Fabry Registry. Mol Genet Metab. Mar. 2012;105(3):443-9. [pmid: 22227322].
100 Wraith JE, Tylki-Szymanska A, Guffon N, et al. Safety and efficacy of enzyme replacement therapy with agalsidase beta: an international, open-label study in pediatric patients with Fabry disease. J Pediatr. Apr. 2008;152(4):563-70. 70 e1. [pmid: 18346516].
101 Wuest W, Machann W, Breunig F, et al. Right ventricular involvement in patients with Fabry’s disease and the effect of enzyme replacement therapy. Rofo. Nov. 2011;183(11):1037-42. [pmid: 21959886].

## Type I Gaucher Disease

1 Gaucher disease. Current issues in diagnosis and treatment. NIH Technology Assessment Panel on Gaucher Disease. JAMA. Feb. 21. 1996;275(7):548-53. [pmid: 8606477].
2 Aerts JM, Yasothan U, Kirkpatrick P. Velaglucerase alfa. Nat Rev Drug Discov. Nov. 2010;9(11):837-8. [pmid: 21030995].
3 Andersson H, Kaplan P, Kacena K, et al. Eight-year clinical outcomes of long-term enzyme replacement therapy for 884 children with Gaucher disease type 1. Pediatrics. Dec. 2008;122(6):1182-90. [pmid: 19047232].
4 Andersson HC, Charrow J, Kaplan P, et al. Individualization of long-term enzyme replacement therapy for Gaucher disease. Genet Med. Feb. 2005;7(2):105-10. [pmid: 15714077].
5 Arikan-Ayyildiz Z, Yuce A, Emre S, et al. Outcome of enzyme replacement therapy in Turkish patients with Gaucher disease: does late intervention affect the response?. Turk J Pediatr. Sep–Oct. 2011;53(5):499-507. [pmid: 22272449].
6 Arikan-Ayyildiz Z, Yuce A, Uslu-Kizilkan N, et al. Immunoglobulin abnormalities and effects of enzyme replacement therapy in children with Gaucher disease. Pediatr Blood Cancer. Apr. 2011;56(4):664-6. [pmid: 21298757].
7 Barranger JA. Risks of Gaucher’s treatment. Lancet. Oct. 14. 2000;356(9238):1353-4. [pmid: 11073045].
8 Barton NW, Brady RO, Dambrosia JM, et al. Replacement therapy for inherited enzyme deficiency–macrophage-targeted glucocerebrosidase for Gaucher’s disease. N Engl J Med. May. 23. 1991;324(21):1464-70. [pmid: 2023606].
9 Barton NW, Furbish FS, Murray GJ, et al. Therapeutic response to intravenous infusions of glucocerebrosidase in a patient with Gaucher disease. Proc Natl Acad Sci U S A. Mar. 1990;87(5):1913-6. [pmid: 2308952].
10 Beck M. New therapeutic options for lysosomal storage disorders: Enzyme replacement, small molecules and gene therapy. Human Genetics. 2007;121(1):1-22. [pmid: 17089160].
11 Belmatoug N, De Villemeur TB. Skeletal response to enzyme replacement therapy for type 1 Gaucher disease: A preliminary report of the French experience. Seminars in Hematology. 3. 1995;32(SUPPL 1):33-8. [pmid: 8821207].
12 Bembi B, Ciana G, Mengel E, et al. Bone complications in children with Gaucher disease. Br J Radiol. 2002;75(Suppl 1):A37-44. [pmid: 12036831].
13 Bembi B, Deegan P. Gaucher disease: improving management. Acta Paediatr Suppl. Apr. 2008;97(457):81-2. [pmid: 18339194].
14 Bembi B, Zanatta M, Carrozzi M, et al. Enzyme replacement treatment in type 1 and type 3 Gaucher’s disease. Lancet. Dec. 17. 1994;344(8938):1679-82. [pmid: 7996964].
15 Benedik-Dolnicar M, Kitanovski L. Individualized long-term enzyme therapy for Gaucher disease type 1 in Slovenia. Pediatrics International. 2011;53(6):1018-22. [pmid: 21883686].
16 Beutler E. Enzyme replacement therapy for Gaucher’s disease. Baillieres Clin Haematol. Dec. 1997;10(4):751-63. [pmid: 9497862].
17 Beutler E, Kay A, Saven A, et al. Enzyme replacement therapy for Gaucher disease. Blood. Sep. 1. 1991;78(5):1183-9. [pmid: 1878585].
18 Boiret-Dupre N, Descamps S, Coudore MA, et al. Effects of imiglucerase treatment on traumatic fracture and bone and blood abnormalities in a patient with previously untreated type 1 gaucher disease. Clin Ther. Dec. 2009;31(12):2900-4. [pmid: 20110029].
19 Brady RO. Emerging strategies for the treatment of hereditary metabolic storage disorders. Rejuvenation Res. Summer. 2006;9(2):237-44. [pmid: 16706651].
20 Burrow TA, Grabowski GA. Velaglucerase alfa in the treatment of Gaucher disease type 1. Clin Investig (Lond). Feb. 2011;1(2):285-93. [pmid: 21927713].
21 Charrow J. Enzyme replacement therapy for Gaucher disease. Expert Opinion on Biological Therapy. 2009;9(1):121-31. [pmid: 19063698].
22 Charrow J, Andersson HC, Kaplan P, et al. Enzyme replacement therapy and monitoring for children with type 1 Gaucher disease: consensus recommendations. J Pediatr. Jan. 2004;144(1):112-20. [pmid: 14722528].
23 Chippington S, McHugh K, Vellodi A. Splenic nodules in paediatric Gaucher disease treated by enzyme replacement therapy. Pediatr Radiol. Jun. 2008;38(6):657-60. [pmid: 18379770].
24 Cleary JE, Burke WM, Baxi LV. Pregnancy after avascular necrosis of the femur complicating Gaucher’s disease. Am J Obstet Gynecol. Jan. 2001;184(2):233-4. [pmid: 11174510].
25 Cohen IJ, Katz K, Kornreich L, et al. Low-dose high-frequency enzyme replacement therapy prevents fractures without complete suppression of painful bone crises in patients with severe juvenile onset type I Gaucher disease. Blood Cells Mol Dis. Sep. 1998;24(3):296-302. [pmid: 10087987].
26 Connock M, Burls A, Frew E, et al. The clinical effectiveness and cost-effectiveness of enzyme replacement therapy for Gaucher’s disease: a systematic review. Health Technol Assess. Jul. 2006;10(24):iii-iv. ix. 136. [pmid: 16796930].
27 de Fost M, Aerts JM, Groener JE, et al. Low frequency maintenance therapy with imiglucerase in adult type I Gaucher disease: a prospective randomized controlled trial. Haematologica. Feb. 2007;92(2):215-21. [pmid: 17296571].
28 Decaux O, Ruelland A, Grosbois B. Effect of treatment on biclonal gammopathy associated with Gaucher disease. J Inherit Metab Dis. Oct. 2007;30(5):824. [pmid: 17879146].
29 Doneda D, Lopes AL, Oliveira AR, et al. Gaucher disease type I: assessment of basal metabolic rate in patients from southern Brazil. Blood Cells Mol Dis. Jan. 15. 2011;46(1):42-6. [pmid: 21075022].
30 Dweck A, Abrahamov A, Hadas-Halpern I, et al. Type I Gaucher disease in children with and without enzyme therapy. Pediatr Hematol Oncol. Sep. 2002;19(6):389-97. [pmid: 12186361].
31 Elstein D. Recent advances in treatment approaches to Gaucher disease. Curr Pharm Biotechnol. Jun. 2011;12(6):854-60. [pmid: 21235447].
32 Elstein D, Abrahamov A, Hadas-Halpern I, et al. Low-dose low-frequency imiglucerase as a starting regimen of enzyme replacement therapy for patients with type I Gaucher disease. QJM. Jul. 1998;91(7):483-8. [pmid: 9797931].
33 Elstein D, Abrahamov A, Itzchaki M, et al. Commentary: low-dose high-frequency enzyme replacement therapy prevents fractures without complete suppression of painful bone crises in patients with severe juvenile onset type I Gaucher disease. Blood Cells Mol Dis. Sep. 1998;24(3):303-5. discussion 6–8. [pmid: 10087988].
34 Elstein D, Cohn GM, Wang N, et al. Early achievement and maintenance of the therapeutic goals using velaglucerase alfa in type 1 Gaucher disease. Blood Cells Mol Dis. Jan. 15. 2011;46(1):119-23. [pmid: 20727796].
35 Elstein D, Foldes AJ, Zahrieh D, et al. Significant and continuous improvement in bone mineral density among type 1 Gaucher disease patients treated with velaglucerase alfa: 69-month experience, including dose reduction. Blood Cells Mol Dis. Jun. 15. 2011;47(1):56-61. [pmid: 21536468].
36 Elstein D, Granovsky-Grisaru S, Rabinowitz R, et al. Use of enzyme replacement therapy for Gaucher disease during pregnancy. Am J Obstet Gynecol. Dec. 1997;177(6):1509-12. [pmid: 9423759].
37 Elstein D, Hadas-Halpern I, Itzchaki M, et al. Effect of low-dose enzyme replacement therapy on bones in Gaucher disease patients with severe skeletal involvement. Blood Cells Mol Dis. 1996;22(2):104-11. discussion 12–4. [pmid: 8931951].
38 Elstein D, Zimran A. Review of the safety and efficacy of imiglucerase treatment of Gaucher disease. Biologics. 2009;3:407-17. [pmid: 19774208].
39 Erdemir G, Ozkan T, Ozgur T, et al. Pediatric gaucher experience in South Marmara region of Turkey. Turkish Journal of Gastroenterology. 2011;22(5):500-4. [pmid: 22234757].
40 Fallet S, Grace ME, Sibille A, et al. Enzyme augmentation in moderate to life-threatening Gaucher disease. Pediatr Res. May. 1992;31(5):496-502. [pmid: 1603627].
41 George MD, Pearse MF. Cemented revision total hip arthroplasty with impaction bone grafting in Gaucher’s disease. J Arthroplasty. Aug. 2002;17(5):667-9. [pmid: 12168187].
42 Germain DP. Gaucher’s disease: a paradigm for interventional genetics. Clin Genet. Feb. 2004;65(2):77-86. [pmid: 14984463].
43 Giraldo P, Irun P, Alfonso P, et al. Evaluation of Spanish Gaucher disease patients after a 6-month imiglucerase shortage. Blood Cells Mol Dis. Jan. 15. 2011;46(1):115-8. [pmid: 20934891].
44 Goker-Alpan O. Optimal therapy in Gaucher disease. Ther Clin Risk Manag. 2010;6:315-23. [pmid: 20668714].
45 Goldblatt J, Fletcher JM, McGill J, et al. Enzyme replacement therapy "drug holiday": results from an unexpected shortage of an orphan drug supply in Australia. Blood Cells Mol Dis. Jan. 15. 2011;46(1):107-10. [pmid: 20684886].
46 Goldblatt J, Szer J, Fletcher JM, et al. Enzyme replacement therapy for Gaucher disease in Australia. Intern Med J. Mar. 2005;35(3):156-61. [pmid: 15737135].
47 Grabowski GA, Barton NW, Pastores G, et al. Enzyme therapy in type 1 Gaucher disease: comparative efficacy of mannose-terminated glucocerebrosidase from natural and recombinant sources. Ann Intern Med. Jan. 1. 1995;122(1):33-9. [pmid: 7985893].
48 Grabowski GA, Kacena K, Cole JA, et al. Dose-response relationships for enzyme replacement therapy with imiglucerase/alglucerase in patients with Gaucher disease type 1. Genet Med. Feb. 2009;11(2):92-100. [pmid: 19265748].
49 Grigorescu Sido P, Drugan C, Cret V, et al. Outcome of enzyme replacement therapy in patients with Gaucher disease type I. The Romanian experience. J Inherit Metab Dis. Oct. 2007;30(5):783-9. [pmid: 17703370].
50 Grigorescu-Sido P, Drugan C, Alkhzouz C, et al. Baseline characteristics and outcome in Romanian patients with Gaucher disease type 1. Eur J Intern Med. Apr. 2010;21(2):104-13. [pmid: 20206881].
51 Grinzaid KA, Geller E, Hanna SL, et al. Cessation of enzyme replacement therapy in Gaucher disease. Genet Med. Nov–Dec. 2002;4(6):427-33. [pmid: 12509713].
52 Hayes RP, Grinzaid KA, Duffey EB, et al. The impact of Gaucher disease and its treatment on quality of life. Qual Life Res. Aug. 1998;7(6):521-34. [pmid: 9737142].
53 Heitner R, Arndt S, Levin JB. Imiglucerase low-dose therapy for paediatric Gaucher disease–a long-term cohort study. S Afr Med J. Aug. 2004;94(8):647-51. [pmid: 15352589].
54 Hill SC, Parker CC, Brady RO, et al. MRI of multiple platyspondyly in Gaucher disease: response to enzyme replacement therapy. J Comput Assist Tomogr. Sep–Oct. 1993;17(5):806-9. [pmid: 8370839].
55 Hollak CE, Aerts JM, van Oers MH. Alglucerase: practical guidance on appropriate dosage and administration in patients with Gaucher disease. BioDrugs. Jan. 1998;9(1):11-23. [pmid: 18020553].
56 Hollak CE, Corssmit EP, Aerts JM, et al. Differential effects of enzyme supplementation therapy on manifestations of type 1 Gaucher disease. Am J Med. Sep. 1997;103(3):185-91. [pmid: 9316550].
57 Hollak CE, de Fost M, van Dussen L, et al. Enzyme therapy for the treatment of type 1 Gaucher disease: clinical outcomes and dose - response relationships. Expert Opin Pharmacother. Nov. 2009;10(16):2641-52. [pmid: 19743939].
58 Hollak CE, Goudsmit R, van Oers MH. Low-dose versus high-frequency regimens in Gaucher’s disease. Lancet. Feb. 10. 1996;347(8998):406-7. [pmid: 8598739].
59 Hollak CE, vom Dahl S, Aerts JM, et al. Force majeure: therapeutic measures in response to restricted supply of imiglucerase (Cerezyme) for patients with Gaucher disease. Blood Cells Mol Dis. Jan. 15. 2010;44(1):41-7. [pmid: 19804996].
60 Hsu CC, Chien YH, Lai MY, et al. Enzyme replacement therapy with imiglucerase in Taiwanese patients with type I Gaucher disease. J Formos Med Assoc. Sep. 2002;101(9):627-31. [pmid: 12645190].
61 Ida H, Rennert OM, Kobayashi M, et al. Effects of enzyme replacement therapy in thirteen Japanese paediatric patients with Gaucher disease. Eur J Pediatr. Jan. 2001;160(1):21-5. [pmid: 11195013].
62 Kishnani PS, DiRocco M, Kaplan P, et al. A randomized trial comparing the efficacy and safety of imiglucerase (Cerezyme) infusions every 4 weeks versus every 2 weeks in the maintenance therapy of adult patients with Gaucher disease type 1. Mol Genet Metab. Apr. 2009;96(4):164-70. [pmid: 19195916].
63 Lachmann RH. Enzyme replacement therapy for lysosomal storage diseases. Current Opinion in Pediatrics. 2011;23(6):588-93. [pmid: 21946346].
64 Lin HY, Lin SP, Chuang CK, et al. Enzyme replacement therapy with imiglucerase in a Taiwanese child with type 1 Gaucher disease. J Chin Med Assoc. May. 2006;69(5):228-32. [pmid: 16835986].
65 Lo SM, Liu J, Chen F, et al. Pulmonary vascular disease in Gaucher disease: clinical spectrum, determinants of phenotype and long-term outcomes of therapy. J Inherit Metab Dis. Jun. 2011;34(3):643-50. [pmid: 21445609].
66 Mikosch P, Reed M, Baker R, et al. Changes of bone metabolism in seven patients with Gaucher disease treated consecutively with imiglucerase and miglustat. Calcif Tissue Int. Jul. 2008;83(1):43-54. [pmid: 18553043].
67 Mistry P, Germain DP. Therapeutic goals in Gaucher disease. Rev Med Interne. Mar. 2006;27(Suppl 1):S30-8. [pmid: 16644400].
68 Mistry PK, Deegan P, Vellodi A, et al. Timing of initiation of enzyme replacement therapy after diagnosis of type 1 Gaucher disease: effect on incidence of avascular necrosis. Br J Haematol. Nov. 2009;147(4):561-70. [pmid: 19732054].
69 Mistry PK, Sirrs S, Chan A, et al. Pulmonary hypertension in type 1 Gaucher’s disease: genetic and epigenetic determinants of phenotype and response to therapy. Mol Genet Metab. Sep–Oct. 2002;77(1–2):91-8. [pmid: 12359135].
70 Mistry PK, Weinreb NJ, Kaplan P, et al. Osteopenia in Gaucher disease develops early in life: response to imiglucerase enzyme therapy in children, adolescents and adults. Blood Cells Mol Dis. Jan. 15. 2011;46(1):66-72. [pmid: 21112800].
71 Mitrovic M, Antic D, Elezovic I, et al. Haemostatic abnormalities in treatment-naive patients with Type 1 Gaucher’s disease. Platelets. 2012;23(2):143-9. [pmid: 21767238].
72 Morales LE. Gaucher’s disease: a review. Ann Pharmacother. Apr. 1996;30(4):381-8. [pmid: 8729893].
73 Morris JL. Velaglucerase alfa for the management of type 1 Gaucher disease. Clin Ther. Feb. 2012;34(2):259-71. [pmid: 22264444].
74 Mota RM, Mankin H. Use of plain radiography to optimize skeletal outcomes in children with type 1 Gaucher disease in Brazil. J Pediatr Orthop. Apr–May. 2007;27(3):347-50. [pmid: 17414023].
75 Nagral A, Mewawalla P, Jagadeesh S, et al. Recombinant macrophage targeted enzyme replacement therapy for Gaucher disease in India. Indian Pediatrics. 2011;48(10):779-84. [pmid: 22080680].
76 Niederau C, Holderer A, Heintges T, et al. Glucocerebrosidase for treatment of Gaucher’s disease: first German long-term results. J Hepatol. Oct. 1994;21(4):610-7. [pmid: 7814809].
77 Niederau C, vom Dahl S, Haussinger D. First long-term results of imiglucerase therapy of type 1 Gaucher disease. Eur J Med Res. Feb. 21. 1998;3(1–2):25-30. [pmid: 9512964].
78 Parisi MS, Mastaglia SR, Bagur A, et al. Body composition and bone metabolism in young Gaucher disease type I patients treated with imiglucerase. Eur J Med Res. Jan. 23. 2008;13(1):31-8. [pmid: 18226995].
79 Pastores GM. Velaglucerase alfa, a human recombinant glucocerebrosidase enzyme replacement therapy for type 1 Gaucher disease. Curr Opin Investig Drugs. Apr. 2010;11(4):472-8. [pmid: 20336596].
80 Pastores GM. Recombinant glucocerebrosidase (imiglucerase) as a therapy for Gaucher disease. BioDrugs. Feb. 1. 2010;24(1):41-7. [pmid: 20055531].
81 Pastores GM, Barnett NL. Current and emerging therapies for the lysosomal storage disorders. Expert Opinion on Emerging Drugs. 2005;10(4):891-902. [pmid: 16262569].
82 Pastores GM, Hermann G, Norton K, et al. Resolution of a proximal humeral defect in type-1 Gaucher disease by enzyme replacement therapy. Pediatr Radiol. 1995;25(6):486-7. [pmid: 7491212].
83 Pastores GM, Hermann G, Norton KI, et al. Regression of skeletal changes in type 1 Gaucher disease with enzyme replacement therapy. Skeletal Radiol. Jul. 1996;25(5):485-8. [pmid: 8837283].
84 Pastores GM, Hughes DA. Gaucher Disease. 1993. [pmid: 20301446].
85 Perel Y, Bioulac-Sage P, Chateil JF, et al. Gaucher’s disease and fatal hepatic fibrosis despite prolonged enzyme replacement therapy. Pediatrics. Jun. 2002;109(6):1170-3. [pmid: 12042560].
86 Perez-Calvo J, Giraldo P, Pastores GM, et al. Extended interval between enzyme therapy infusions for adult patients with Gaucher’s disease type 1. J Postgrad Med. Apr–Jun. 2003;49(2):127-31. [pmid: 12867687].
87 Piran S, Amato D. Gaucher disease: a systematic review and meta-analysis of bone complications and their response to treatment. J Inherit Metab Dis. Jun. 2010;33(3):271-9. [pmid: 20336376].
88 Poll LW, Koch JA, vom Dahl S, et al. Magnetic resonance imaging of bone marrow changes in Gaucher disease during enzyme replacement therapy: first German long-term results. Skeletal Radiol. Sep. 2001;30(9):496-503. [pmid: 11587517].
89 Rudzki Z, Okon K, Machaczka M, et al. Enzyme replacement therapy reduces Gaucher cell burden but may accelerate osteopenia in patients with type I disease - a histological study. Eur J Haematol. May. 2003;70(5):273-81. [pmid: 12694162].
90 Schiffmann R, Mankin H, Dambrosia JM, et al. Decreased bone density in splenectomized Gaucher patients receiving enzyme replacement therapy. Blood Cells Mol Dis. Mar–Apr. 2002;28(2):288-96. [pmid: 12064924].
91 Sekijima Y, Ohashi T, Ohira S, et al. Successful pregnancy and lactation outcome in a patient with Gaucher disease receiving enzyme replacement therapy, and the subsequent distribution and excretion of imiglucerase in human breast milk. Clin Ther. Nov. 2010;32(12):2048-52. [pmid: 21118740].
92 Shah U, Nadeem N, Husen Y, et al. Imiglucerase treatment in Gaucher’s disease. J Ayub Med Coll Abbottabad. Apr–Jun. 2007;19(2):56-9. [pmid: 18183722].
93 Sims KB, Pastores GM, Weinreb NJ, et al. Improvement of bone disease by imiglucerase (Cerezyme) therapy in patients with skeletal manifestations of type 1 Gaucher disease: results of a 48-month longitudinal cohort study. Clin Genet. May. 2008;73(5):430-40. [pmid: 18312448].
94 Starzyk K, Richards S, Yee J, et al. The long-term international safety experience of imiglucerase therapy for Gaucher disease. Mol Genet Metab. Feb. 2007;90(2):157-63. [pmid: 17079176].
95 Stirnemann J, Boutten A, Vincent C, et al. Impact of imiglucerase on the serum glycosylated-ferritin level in Gaucher disease. Blood Cells Mol Dis. Jan. 15. 2011;46(1):34-8. [pmid: 21084203].
96 Toth J, Erdos M, Marodi L. Rebound hepatosplenomegaly in type 1 Gaucher disease. Eur J Haematol. Feb. 2003;70(2):125-8. [pmid: 12581195].
97 Weinreb N, Barranger J, Packman S, et al. Imiglucerase (Cerezyme) improves quality of life in patients with skeletal manifestations of Gaucher disease. Clin Genet. Jun. 2007;71(6):576-88. [pmid: 17539908].
98 Weinreb N, Taylor J, Cox T, et al. A benchmark analysis of the achievement of therapeutic goals for type 1 Gaucher disease patients treated with imiglucerase. Am J Hematol. Dec. 2008;83(12):890-5. [pmid: 18819093].
99 Weinreb NJ. Imiglucerase and its use for the treatment of Gaucher’s disease. Expert Opin Pharmacother. Aug. 2008;9(11):1987-2000. [pmid: 18627336].
100 Weinreb NJ, Charrow J, Andersson HC, et al. Effectiveness of enzyme replacement therapy in 1028 patients with type 1 Gaucher disease after 2 to 5 years of treatment: a report from the Gaucher Registry. Am J Med. Aug. 1. 2002;113(2):112-9. [pmid: 12133749].
101 Wenstrup RJ, Kacena KA, Kaplan P, et al. Effect of enzyme replacement therapy with imiglucerase on BMD in type 1 Gaucher disease. J Bone Miner Res. Jan. 2007;22(1):119-26. [pmid: 17032149].
102 Wilson C, Spearing R, Teague L, et al. The outcome of clinical parameters in adults with severe Type I Gaucher disease using very low dose enzyme replacement therapy. Mol Genet Metab. Sep–Oct. 2007;92(1–2):131-6. [pmid: 17604204].
103 Wine E, Yaniv I, Cohen IJ. Hyperimmunoglobulinemia in pediatric-onset type 1 Gaucher disease and effects of enzyme replacement therapy. J Pediatr Hematol Oncol. Jul. 2007;29(7):451-7. [pmid: 17609622].
104 Wraith JE. Limitations of enzyme replacement therapy: Current and future. Journal of Inherited Metabolic Disease. 2006;29(2–3):442-7. [pmid: 16763916].
105 Yalcin K, Ucmak F, Bestas R, et al. Gaucher’s disease presenting with massive hepatic fibrosis and skeletal abnormalities: A case report with review of the literature. Turkiye Klinikleri Journal of Medical Sciences. 2011;31(3):752-8.
106 Zhao H, Bailey LA, Grabowski GA. Enzyme therapy of gaucher disease: clinical and biochemical changes during production of and tolerization for neutralizing antibodies. Blood Cells Mol Dis. Jan–Feb. 2003;30(1):90-6. [pmid: 12667990].
107 Zimran A. Velaglucerase alfa: a new option for Gaucher disease treatment. Drugs Today (Barc). Jul. 2011;47(7):515-29. [pmid: 22013559].
108 Zimran A, Altarescu G, Philips M, et al. Phase 1/2 and extension study of velaglucerase alfa replacement therapy in adults with type 1 Gaucher disease: 48-month experience. Blood. Jun. 10. 2010;115(23):4651-6. [pmid: 20299511].
109 Zimran A, Elstein D, Abrahamov A. Enzyme replacement therapy in type 1 and type 3 Gaucher’s disease. Lancet. Feb. 18. 1995;345(8947):451-2. [pmid: 7853968].
110 Zimran A, Elstein D, Levy-Lahad E, et al. Replacement therapy with imiglucerase for type 1 Gaucher’s disease. Lancet. Jun. 10. 1995;345(8963):1479-80. [pmid: 7769903].
111 Zimran A, Hollak CE, Abrahamov A, et al. Home treatment with intravenous enzyme replacement therapy for Gaucher disease: an international collaborative study of 33 patients. Blood. Aug. 15. 1993;82(4):1107-9. [pmid: 8353277].
112 Zimran A, Morris E, Mengel E, et al. The female Gaucher patient: the impact of enzyme replacement therapy around key reproductive events (menstruation, pregnancy and menopause). Blood Cells Mol Dis. Nov–Dec. 2009;43(3):264-88. [pmid: 19502088].

## MPS I

1 Laronidase. BioDrugs. 2002;16(4):316-8. [pmid: 12196045].
2 Laronidase. Prescrire International. 2004;13(74):217.
3 Anbu AT, Mercer J, Wraith JE. Effect of discontinuing of laronidase in a patient with mucopolysaccharidosis type I. J Inherit Metab Dis. Feb. 2006;29(1):230-1. [pmid: 16601901].
4 Arora RS, Mercer J, Thornley M, et al. Enzyme replacement therapy in 12 patients with MPS I-H/S with homozygous p. Leu490Pro mutation. J Inherit Metab Dis. Oct. 2007;30(5):821. [pmid: 17570076].
5 Caceres-Marzal C, Garcia-Reymundo M, Solana J, et al. Decreased corneal opacity and improved vision in a patient with mucopolysaccharidosis I (Hurler-Scheie) treated with enzyme replacement therapy (laronidase, Aldurazyme). Am J Med Genet A. Jul. 1. 2008;146A(13):1768-70. [pmid: 18546328].
6 Chen A, Dickson P. Intrathecal enzyme replacement therapy to treat spinal cord compression in mucopolysaccharidosis: Overview and rationale. Journal of Pediatric Rehabilitation Medicine. 2010;3(1):7-11. [pmid: 21791827].
7 Clarke LA, Heppner J. Mucopolysaccharidosis Type I. 1993. [pmid: 20301341].
8 Clarke LA, Wraith JE, Beck M, et al. Long-term efficacy and safety of laronidase in the treatment of mucopolysaccharidosis I. Pediatrics. Jan. 2009;123(1):229-40. [pmid: 19117887].
9 El Dib RP, Pastores GM. Laronidase for treating mucopolysaccharidosis type I. Genet Mol Res. 2007;6(3):667-74. [pmid: 18050087].
10 Giugliani R, Rojas VM, Martins AM, et al. A dose-optimization trial of laronidase (Aldurazyme) in patients with mucopolysaccharidosis I. Mol Genet Metab. Jan. 2009;96(1):13-9. [pmid: 19038563].
11 Grewal SS, Wynn R, Abdenur JE, et al. Safety and efficacy of enzyme replacement therapy in combination with hematopoietic stem cell transplantation in Hurler syndrome. Genet Med. Feb. 2005;7(2):143-6. [pmid: 15714083].
12 Harada H, Uchiwa H, Nakamura M, et al. Laronidase replacement therapy improves myocardial function in mucopolysaccharidosis I. Mol Genet Metab. Jul. 2011;103(3):215-9. [pmid: 21482163].
13 Hirth A, Berg A, Greve G. Successful treatment of severe heart failure in an infant with Hurler syndrome. J Inherit Metab Dis. Oct. 2007;30(5):820. [pmid: 17768668].
14 Hoffmann B, Schulze-Frenking G, Al-Sawaf S, et al. Hunter disease before and during enzyme replacement therapy. Pediatric Neurology. 2011;45(3):181-4. [pmid: 21824567].
15 Kakkis ED. Enzyme replacement therapy for the mucopolysaccharide storage disorders. Expert Opinion on Investigational Drugs. 2002;11(5):675-85. [pmid: 11996648].
16 Kishnani PS, BurnsWechsler S, Li JS. Enzyme-deficiency metabolic cardiomyopathies and the role of enzyme replacement therapy. Progress in Pediatric Cardiology. 2007;23(1–2):39-48.
17 Lin HY, Lin SP, Chuang CK, et al. Mucopolysaccharidosis I under enzyme replacement therapy with laronidase–a mortality case with autopsy report. J Inherit Metab Dis. 2005;28(6):1146-8. [pmid: 16435211].
18 McIntyre JA. Laronidase: Treatment of mucopolysaccharidosis I. Drugs of the Future. 2003;28(5):432-4.
19 Miebach E. Enzyme replacement therapy in mucopolysaccharidosis type I. Acta Paediatr Suppl. Mar. 2005;94(447):58-60. discussion 57. [pmid: 15895714].
20 Muenzer J, Wraith JE, Clarke LA. Mucopolysaccharidosis I: Management and treatment guidelines. Pediatrics. 2009;123(1):19-29. [pmid: 19117856].
21 Munoz-Rojas MV, Vieira T, Costa R, et al. Intrathecal enzyme replacement therapy in a patient with mucopolysaccharidosis type I and symptomatic spinal cord compression. Am J Med Genet A. Oct. 1. 2008;146A(19):2538-44. [pmid: 18792977].
22 Murillo-Lopez FH. Mucopolysaccharidosis type I therapy. Annals of Ophthalmology. 2005;37(4):235-6.
23 Pastores GM. Laronidase (Aldurazyme): enzyme replacement therapy for mucopolysaccharidosis type I. Expert Opin Biol Ther. Jul. 2008;8(7):1003-9. [pmid: 18549329].
24 Pastores GM. Therapeutic options for childhood-onset lysosomal storage disorders. Pediatric Health. 2008;2(1):21-32.
25 Pitz S, Ogun O, Bajbouj M, et al. Ocular changes in patients with mucopolysaccharidosis I receiving enzyme replacement therapy: a 4-year experience. Arch Ophthalmol. Oct. 2007;125(10):1353-6. [pmid: 17923542].
26 Rohrbach M, Clarke JTR. Treatment of lysosomal storage disorders: Progress with enzyme replacement therapy. Drugs. 2007;67(18):2697-716. [pmid: 18062719].
27 Sakuraba H, Sawada M, Matsuzawa F, et al. Molecular pathologies of and enzyme replacement therapies for lysosomal diseases. CNS and Neurological Disorders - Drug Targets. 2006;5(4):401-13. [pmid: 16918392].
28 Sifuentes M, Doroshow R, Hoft R, et al. A follow-up study of MPS I patients treated with laronidase enzyme replacement therapy for 6 years. Mol Genet Metab. Feb. 2007;90(2):171-80. [pmid: 17011223].
29 Soutar RL, Mercer J, Wraith JE. Impact of 144 weeks of laronidase therapy on body functions, endurance and general well-being in a Hurler-Scheie patient. J Inherit Metab Dis. Aug. 2006;29(4):590. [pmid: 16830264].
30 Thomas JA, Jacobs S, Kierstein J, et al. Outcome after three years of laronidase enzyme replacement therapy in a patient with Hurler syndrome. J Inherit Metab Dis. Dec. 2006;29(6):762. [pmid: 17089217].
31 Tokic V, Barisic I, Huzjak N, et al. Enzyme replacement therapy in two patients with an advanced severe (Hurler) phenotype of mucopolysaccharidosis I. Eur J Pediatr. Jul. 2007;166(7):727-32. [pmid: 17043838].
32 Tolar J, Grewal SS, Bjoraker KJ, et al. Combination of enzyme replacement and hematopoietic stem cell transplantation as therapy for Hurler syndrome. Bone Marrow Transplantation. 2008;41(6):531-5. [pmid: 18037941].
33 Tylki-Szymanska A, Marucha J, Jurecka A, et al. Efficacy of recombinant human alpha-L-iduronidase (laronidase) on restricted range of motion of upper extremities in mucopolysaccharidosis type I patients. J Inherit Metab Dis. Apr. 2010;33(2):151-7. [pmid: 20217237].
34 Tylki-Szymanska A, Rozdzynska A, Jurecka A, et al. Anthropometric data of 14 patients with mucopolysaccharidosis I: retrospective analysis and efficacy of recombinant human alpha-L-iduronidase (laronidase). Mol Genet Metab. Jan. 2010;99(1):10-7. [pmid: 19783188].
35 Valayannopoulos V, Boddaert N, Barbier V, et al. Cognitive and neuroradiological improvement in three patients with attenuated MPS I treated by laronidase. Mol Genet Metab. May. 2010;100(1):20-3. [pmid: 20106688].
36 Valayannopoulos V, Wijburg FA. Therapy for the mucopolysaccharidoses. Rheumatology (Oxford). Dec. 2011;50(Suppl 5):v49-59. [pmid: 22210671].
37 Viana GM, de Lima NO, Cavaleiro R, et al. Mucopolysaccharidoses in northern Brazil: Targeted mutation screening and urinary glycosaminoglycan excretion in patients undergoing enzyme replacement therapy. Genetics and Molecular Biology. 2011;34(3):410-5. [pmid: 21931511].
38 Wang RY, Bodamer OA, Watson MS, et al. Lysosomal storage diseases: diagnostic confirmation and management of presymptomatic individuals. Genet Med. May. 2011;13(5):457-84. [pmid: 21502868].
39 Wraith EJ, Hopwood JJ, Fuller M, et al. Laronidase treatment of mucopolysaccharidosis I. BioDrugs. 2005;19(1):1-7. [pmid: 15691212].
40 Wraith JE. The first 5 years of clinical experience with laronidase enzyme replacement therapy for mucopolysaccharidosis I. Expert Opin Pharmacother. Mar. 2005;6(3):489-506. [pmid: 15794739].
41 Wraith JE, Beck M, Lane R, et al. Enzyme replacement therapy in patients who have mucopolysaccharidosis I and are younger than 5 years: results of a multinational study of recombinant human alpha-L-iduronidase (laronidase). Pediatrics. Jul. 2007;120(1):e37-46. [pmid: 17606547].
42 Wraith JE, Clarke LA, Beck M, et al. Enzyme replacement therapy for mucopolysaccharidosis I: a randomized, double-blinded, placebo-controlled, multinational study of recombinant human alpha-L-iduronidase (laronidase). J Pediatr. May. 2004;144(5):581-8. [pmid: 15126990].
43 Wynn RF, Mercer J, Page J, et al. Use of enzyme replacement therapy (Laronidase) before hematopoietic stem cell transplantation for mucopolysaccharidosis I: experience in 18 patients. J Pediatr. Jan. 2009;154(1):135-9. [pmid: 19187736].
44 Yano S, Moseley K, Pavlova Z. Postmortem studies on a patient with mucopolysaccharidosis type I: Histopathological findings after one year of enzyme replacement therapy. J Inherit Metab Dis. 2009. Mar. 27. [pmid: 19308670].
45 Yosunkaya E, Karaca E, Yilmaz SB, et al. Sudden vision loss in a mucopolysaccharidosis I patient receiving enzyme replacement therapy. Genetic Counseling. 2011;22(4):371-6. [pmid: 22303797].

## MPS II

1 Idursulfase: a poor risk-benefit balance in type II mucopolysaccharidosis. Prescrire Int. Jun. 2008;17(95):109. [pmid: 18630351].
2 Alcalde-Martin C, Muro-Tudelilla JM, Cancho-Candela R, et al. First experience of enzyme replacement therapy with idursulfase in Spanish patients with Hunter syndrome under 5 years of age: case observations from the Hunter Outcome Survey (HOS). Eur J Med Genet. Nov–Dec. 2010;53(6):371-7. [pmid: 20709629].
3 Alegra T, Eizerik D, Cerqueira CCS, et al. A systematic literature review: Enzyme replacement therapy in mucopolysaccharidosis type II. Journal of Inherited Metabolic Disease. 2011;34:S230.
4 Bal MO, Zanotti M, Bettocchi I, et al. Idursulfase therapy in a patient affected by muchopolysaccaridosis (MPS) type II. Journal of Inherited Metabolic Disease. 2011;34:S230.
5 Beck M. Mucopolysaccharidosis Type II (Hunter Syndrome): clinical picture and treatment. Curr Pharm Biotechnol. Jun. 2011;12(6):861-6. [pmid: 21235446].
6 Beck M, Wraith E, Muenzer J, et al. Long-term weekly dosing of idursulfase in the treatment of mucopolysaccharidosis II (MPS II, Hunter syndrome) abstract. 2007. http://www.mrw.interscience.wiley.com/cochrane/clcentral/articles/799/CN-00723799/frame.html.
7 Burrow TA, Hopkin RJ, Leslie ND, et al. Enzyme reconstitution/replacement therapy for lysosomal storage diseases. Curr Opin Pediatr. Dec. 2007;19(6):628-35. [pmid: 18025928].
8 Burrow TA, Leslie ND. Review of the use of idursulfase in the treatment of mucopolysaccharidosis II. Biologics. Jun. 2008;2(2):311-20. [pmid: 19707363].
9 Burton BK, Guffon N, Roberts J, et al. Home treatment with intravenous enzyme replacement therapy with idursulfase for mucopolysaccharidosis type II - data from the Hunter Outcome Survey. Mol Genet Metab. Oct–Nov. 2010;101(2–3):123-9. [pmid: 20638311].
10 Burton BK, Whiteman DA. Incidence and timing of infusion-related reactions in patients with mucopolysaccharidosis type II (Hunter syndrome) on idursulfase therapy in the real-world setting: a perspective from the Hunter Outcome Survey (HOS). Mol Genet Metab. Jun. 2011;103(2):113-20. [pmid: 21439875].
11 Galan-Gomez E, Guerrero-Rico A, Caceres-Marzal C, et al. Early response to idursulfase treatment in a 3 year-old boy affected of Hunter syndrome. Eur J Med Genet. May–Jun. 2008;51(3):268-71. [pmid: 18396123].
12 Jones SA, Almassy Z, Beck M, et al. Mortality and cause of death in mucopolysaccharidosis type II-a historical review based on data from the Hunter Outcome Survey (HOS). J Inherit Metab Dis. Aug. 2009;32(4):534-43. [pmid: 19597960].
13 Jurecka A, Krumina Z, Zuber Z, et al. Mucopolysaccharidosis type II in females and response to enzyme replacement therapy. American Journal of Medical Genetics, Part A. 2012;158 A(2):450-4. [pmid: 22246721].
14 Manara R, Rampazzo A, Cananzi M, et al. Hunter syndrome in an 11-year old girl on enzyme replacement therapy with idursulfase: brain magnetic resonance imaging features and evolution. J Inherit Metab Dis. 2010. Jan. 6. [pmid: 20052546].
15 Marin LL, Gutierrez-Solana LG, Fernandez AT. Hunter Syndrome: Resolution of Extensive Typical Skin Lesions After 9 Months of Enzyme Replacement Therapy with Idursulfase. Pediatr Dermatol. 2011. Oct. 13. [pmid: 21995841].
16 Miebach E. Management of infusion-related reactions to enzyme replacement therapy in a cohort of patients with mucopolysaccharidosis disorders. Int J Clin Pharmacol Ther. 2009;47(Suppl 1):S100-6. [pmid: 20040319].
17 Muenzer J, Beck M, Eng CM, et al. Multidisciplinary management of Hunter syndrome. Pediatrics. Dec. 2009;124(6):e1228-39. [pmid: 19901005].
18 Muenzer J, Beck M, Eng CM, et al. Long-term, open-labeled extension study of idursulfase in the treatment of Hunter syndrome. Genet Med. Feb. 2011;13(2):95-101. [pmid: 21150784].
19 Muenzer J, Beck M, Giugliani R, et al. Idursulfase treatment of Hunter syndrome in children younger than 6 years: results from the Hunter Outcome Survey. Genet Med. Feb. 2011;13(2):102-9. [pmid: 21233716].
20 Muenzer J, Bodamer O, Burton B, et al. The role of enzyme replacement therapy in severe Hunter syndrome-an expert panel consensus. Eur J Pediatr. Jan. 2012;171(1):181-8. [pmid: 22037758].
21 Muenzer J, Gucsavas-Calikoglu M, McCandless SE, et al. A phase I/II clinical trial of enzyme replacement therapy in mucopolysaccharidosis II (Hunter syndrome). Mol Genet Metab. Mar. 2007;90(3):329-37. [pmid: 17185020].
22 Muenzer J, Wraith JE, Beck M, et al. A phase II/III clinical study of enzyme replacement therapy with idursulfase in mucopolysaccharidosis II (Hunter syndrome). Genet Med. Aug. 2006;8(8):465-73. [pmid: 16912578].
23 Okuyama T, Tanaka A, Suzuki Y, et al. Japan Elaprase Treatment (JET) study: idursulfase enzyme replacement therapy in adult patients with attenuated Hunter syndrome (Mucopolysaccharidosis II, MPS II). Mol Genet Metab. Jan. 2010;99(1):18-25. [pmid: 19773189].
24 Papadia F, Lozupone MS, Gaeta A, et al. Long-term enzyme replacement therapy in a severe case of mucopolysaccharidosis type II (Hunter syndrome). Eur Rev Med Pharmacol Sci. Mar. 2011;15(3):253-8. [pmid: 21528770].
25 Scarpa M. Mucopolysaccharidosis Type II. 1993. [pmid: 20301451].
26 Scarpa M, Almassy Z, Beck M, et al. Mucopolysaccharidosis type II: European recommendations for the diagnosis and multidisciplinary management of a rare disease. Orphanet Journal of Rare Diseases. 2011;6(1).
27 Schulze-Frenking G, Jones SA, Roberts J, et al. Effects of enzyme replacement therapy on growth in patients with mucopolysaccharidosis type II. J Inherit Metab Dis. Feb. 2011;34(1):203-8. [pmid: 20978944].
28 Sohn YB, Choi EW, Kim SJ, et al. Retrospective analysis of the clinical manifestations and survival of Korean patients with mucopolysaccharidosis type II: Emphasis on the cardiovascular complication and mortality cases. American Journal of Medical Genetics, Part A. 2012;158 A(1):90-6. [pmid: 22105882].
29 Tylki-Szymanska A, Jurecka A, Rozdzynska A, et al. Enzyme replacement therapy in a 3-month-old boy with presymptomatic MPS II: 3-year follow-up. Journal of Inherited Metabolic Disease. 2011;34:S209.
30 Uz B, Demiroglu H, Ozcebe OI. Hunter syndrome and new onset idiopathic thrombocytopenic purpura in a young patient. Annals of Hematology. 2012;91(2):303-4. [pmid: 21556874].
31 Wraith JE. Enzyme replacement therapy with idursulfase in patients with mucopolysaccharidosis type II. Acta Paediatr Suppl. Apr. 2008;97(457):76-8. [pmid: 18339193].
32 Wraith JE, Scarpa M, Beck M, et al. Mucopolysaccharidosis type II (Hunter syndrome): a clinical review and recommendations for treatment in the era of enzyme replacement therapy. Eur J Pediatr. Mar. 2008;167(3):267-77. [pmid: 18038146].
33 Zareba G. Idursulfase in Hunter syndrome treatment. Drugs Today (Barc). Nov. 2007;43(11):759-67. [pmid: 18174963].

## MPS VI

1 Galsulfase: arylsulfatase B, BM 102, recombinant human arylsulfatase B, recombinant human N-acetylgalactosamine-4-sulfatase, rhASB. Drugs R D. 2005;6(5):312-5. [pmid: 16128602].
2 Beck M. Galsulfase: Enzyme-replacement therapy for mucopolysaccharidosis Type VI (Maroteaux-Lamy syndrome). Therapy. 2006;3(1):9-17.
3 But WM, Wong MY, Chow JCK, et al. Enzyme replacement therapy for mucopolysaccharidosis VI (Maroteaux-Lamy syndrome): Experience in Hong Kong. Hong Kong Medical Journal. 2011;17(4):317-24. [pmid: 21813902].
4 El Dib RP, Pastores GM. A systematic review of new advances in the management of mucopolysaccharidosis VI (Maroteaux-Lamy syndrome): focus on galsulfase. Biologics. 2009;3:459-68. [pmid: 19851471].
5 Furujo M, Kubo T, Kosuga M, et al. Enzyme replacement therapy attenuates disease progression in two Japanese siblings with mucopolysaccharidosis type VI. Molecular Genetics and Metabolism. 2011;104(4):597-602. [pmid: 21930407].
6 Giugliani R, Carvalho CG, Herber S, et al. Recent Advances in Treatment Approaches of Mucopolysaccharidosis VI. Curr Pharm Biotechnol. Jun. 2011;12(6):956-62. [pmid: 21506914].
7 Giugliani R, Harmatz P, Wraith JE. Management guidelines for mucopolysaccharidosis VI. Pediatrics. 2007;120(2):405-18. [pmid: 17671068].
8 Harmatz P. Enzyme replacement therapy with galsulfase for mucopolysaccharidosis VI: clinical facts and figures. Turk J Pediatr. Sep–Oct. 2010;52(5):443-9. [pmid: 21434527].
9 Harmatz P, Ketteridge D, Giugliani R, et al. Direct comparison of measures of endurance, mobility, and joint function during enzyme-replacement therapy of mucopolysaccharidosis VI (Maroteaux-Lamy syndrome): Results after 48 weeks in a phase 2 open-label clinical study of recombinant human N-acetylgalactosamine 4-sulfatase. Pediatrics. 2005;115(6):e681-e9. [pmid: 15930196].
10 Harmatz P, Whitley CB, Waber L, et al. Enzyme replacement therapy in mucopolysaccharidosis VI (Maroteaux-Lamy syndrome). J Pediatr. May. 2004;144(5):574-80. [pmid: 15126989].
11 Harmatz P, Yu ZF, Giugliani R, et al. Enzyme replacement therapy for mucopolysaccharidosis VI: evaluation of long-term pulmonary function in patients treated with recombinant human N-acetylgalactosamine 4-sulfatase. J Inherit Metab Dis. Feb. 2010;33(1):51-60. [pmid: 20140523].
12 Hendriksz CJ, Giugliani R, Harmatz P, et al. Design, baseline characteristics, and early findings of the MPS VI (mucopolysaccharidosis VI) Clinical Surveillance Program (CSP). Journal of Inherited Metabolic Disease. 2011:1-12.
13 Jurecka A, Golda A, Opoka-Winiarska V, et al. Mucopolysaccharidosis Type VI (Maroteaux-Lamy syndrome) with a predominantly cardiac phenotype. Mol Genet Metab. 2011. Aug. 27. [pmid: 21917494].
14 Koseoglu ST, Harmatz P, Turbeville S, et al. Reversed papilledema in an MPS VI patient with galsulfase (Naglazyme) therapy. Int Ophthalmol. Aug. 2009;29(4):267-9. [pmid: 18418554].
15 Pitz S, Ogun O, Arash L, et al. Does enzyme replacement therapy influence the ocular changes in type VI mucopolysaccharidosis?. Graefes Arch Clin Exp Ophthalmol. Jul. 2009;247(7):975-80. [pmid: 19159944].
16 Sohn YB, Park SW, Kim SH, et al. Enzyme replacement therapy improves joint motion and outcome of the 12-min walk test in a mucopolysaccharidosis type VI patient previously treated with bone marrow transplantation. American Journal of Medical Genetics, Part A. 2012.
17 Valayannopoulos V, Nicely H, Harmatz P, et al. Mucopolysaccharidosis VI. Orphanet J Rare Dis. 2010;5:5. [pmid: 20385007].
18 Whitley CB, Utz JR. Maroteaux-Lamy syndrome (mucopolysaccharidosis type VI): a single dose of galsulfase further reduces urine glycosaminoglycans after hematopoietic stem cell transplantation. Mol Genet Metab. Dec. 2010;101(4):346-8. [pmid: 20800524].
19 Wraith JE. Enzyme replacement therapy for the management of the mucopolysaccharidoses. Int J Clin Pharmacol Ther. 2009;47(Suppl 1):S63-5. [pmid: 20040314].

## Pompe Disease

1 Alglucosidase alfa: new drug. Pompe disease: a short-term benefit. Prescrire Int. Dec. 2007;16(92):240-1. [pmid: 18092404].
2 Abbott MA, Prater SN, Banugaria SG, et al. Atypical immunologic response in a patient with CRIM-negative Pompe disease. Mol Genet Metab. 2011. Aug. 11. [pmid: 21889385].
3 Angelini C, Semplicini C. Enzyme replacement therapy for pompe disease. Current Neurology and Neuroscience Reports. 2012;12(1):70-5. [pmid: 22002767].
4 Angelini C, Semplicini C, Tonin P, et al. Progress in enzyme replacement therapy in glycogen storage disease type II. Therapeutic Advances in Neurological Disorders. 2009;2(3):143-53. [pmid: 21179524].
5 Banugaria SG, Patel TT, Mackey J, et al. Persistence of high sustained antibodies to enzyme replacement therapy despite extensive immunomodulatory therapy in an infant with Pompe disease: Need for agents to target antibody-secreting plasma cells. Mol Genet Metab. Apr. 2012;105(4):677-80. [pmid: 22365055].
6 Beck M. Alglucosidase alfa: Long term use in the treatment of patients with Pompe disease. Ther Clin Risk Manag. 2009;5:767-72. [pmid: 19816575].
7 Bernstein DL, Bialer MG, Mehta L, et al. Pompe disease: dramatic improvement in gastrointestinal function following enzyme replacement therapy. A report of three later-onset patients. Mol Genet Metab. Oct–Nov. 2010;101(2–3):130-3. [pmid: 20638881].
8 But WM, Lee SH, Chan AO, et al. Enzyme replacement therapy for infantile Pompe disease during the critical period and identification of a novel mutation. Hong Kong Med J. Dec. 2009;15(6):474-7. [pmid: 19966354].
9 Case LE, Beckemeyer AA, Kishnani PS. Infantile Pompe disease on ERT-Update on clinical presentation, musculoskeletal management, and exercise considerations. American Journal of Medical Genetics, Part C: Seminars in Medical Genetics. 2012;160 C(1):69-79.
10 Case LE, Hanna R, Frush DP, et al. Fractures in children with Pompe disease: a potential long-term complication. Pediatr Radiol. May. 2007;37(5):437-45. [pmid: 17342521].
11 Case LE, Koeberl DD, Young SP, et al. Improvement with ongoing Enzyme Replacement Therapy in advanced late-onset Pompe disease: a case study. Mol Genet Metab. Dec. 2008;95(4):233-5. [pmid: 18930676].
12 Chien YH, Hwu WL. A review of treatment of Pompe disease in infants. Biologics. Sep. 2007;1(3):195-201. [pmid: 19707330].
13 Cho A, Kim SJ, Lim BC, et al. Infantile Pompe disease: Clinical and genetic characteristics with an experience of enzyme replacement therapy. Journal of Child Neurology. 2012;27(3):319-24. [pmid: 21940687].
14 Cook AL, Kishnani PS, Carboni MP, et al. Ambulatory electrocardiogram analysis in infants treated with recombinant human acid alpha-glucosidase enzyme replacement therapy for Pompe disease. Genet Med. May. 2006;8(5):313-7. [pmid: 16702882].
15 Corzo D, Byrne B, Hwu WL, et al. Alglucosidase Alfa (Myozyme(registered trademark)) in Infants and Children with Rapidly Progressive Pompe Disease. Clinical Therapeutics. 2008;30(SUPPL 1):S9-10.
16 Cupler EJ, Berger KI, Leshner RT, et al. Consensus treatment recommendations for late-onset pompe disease. Muscle and Nerve. 2012;45(3):319-33. [pmid: 22173792].
17 De Vries J, Kroos M, Ozkan L, et al. Infusion-associated reactions and neutralizing antibody formation in an adult with pompe disease receiving alglucosidase alfa. Clinical Therapeutics. 2010;32:S72.
18 de Vries JM, Brugma JD, Ozkan L, et al. First experience with enzyme replacement therapy during pregnancy and lactation in Pompe disease. Mol Genet Metab. Dec. 2011;104(4):552-5. [pmid: 21967859].
19 Del Rizzo M, Fanin M, Cerutti A, et al. Long-term follow-up results in enzyme replacement therapy for Pompe disease: a case report. J Inherit Metab Dis. 2010. Sep. 10. [pmid: 20830524].
20 Desnuelle C, Salviati L. Challenges in diagnosis and treatment of late-onset Pompe disease. Current Opinion in Neurology. 2011;24(5):443-8. [pmid: 21892081].
21 Fidzianska A, Lugowska A, Tylki-Szymanska A. Late form of Pompe disease with glycogen storage in peripheral nerves axons. J Neurol Sci. Feb. 15. 2011;301(1–2):59-62. [pmid: 21109266].
22 Fukuda T, Roberts A, Plotz PH, et al. Acid alpha-glucosidase deficiency (Pompe disease). Curr Neurol Neurosci Rep. Jan. 2007;7(1):71-7. [pmid: 17217857].
23 Furusawa Y, Mori-Yoshimura M, Yamamoto T, et al. Effects of enzyme replacement therapy on five patients with advanced late-onset glycogen storage disease type II: a 2-year follow-up study. J Inherit Metab Dis. Mar. 2012;35(2):301-10. [pmid: 21984055].
24 Ishigaki K, Murakami T, Nakanishi T, et al. Close monitoring of initial enzyme replacement therapy in a patient with childhood-onset Pompe disease. Brain and Development. 2012;34(2):98-102. [pmid: 21676566].
25 Jones HN, Moss T, Edwards L, et al. Increased inspiratory and expiratory muscle strength following respiratory muscle strength training (RMST) in two patients with late-onset Pompe disease. Mol Genet Metab. Nov. 2011;104(3):417-20. [pmid: 21641843].
26 Jones HN, Muller CW, Lin M, et al. Oropharyngeal dysphagia in infants and children with infantile Pompe disease. Dysphagia. Dec. 2010;25(4):277-83. [pmid: 19763689].
27 Kishnani PS, Beckemeyer AA, Mendelsohn NJ. The new era of Pompe disease: advances in the detection, understanding of the phenotypic spectrum, pathophysiology, and management. Am J Med Genet C Semin Med Genet. Feb. 15. 2012;160(1):1-7. [pmid: 22253049].
28 Kishnani PS, Corzo D, Leslie ND, et al. Early treatment with alglucosidase alpha prolongs long-term survival of infants with Pompe disease. Pediatr Res. Sep. 2009;66(3):329-35. [pmid: 19542901].
29 Kishnani PS, Corzo D, Nicolino M, et al. Recombinant human acid [alpha]-glucosidase: major clinical benefits in infantile-onset Pompe disease. Neurology. Jan. 9. 2007;68(2):99-109. [pmid: 17151339].
30 Kishnani PS, Nicolino M, Voit T, et al. Results from phase II trial of chinese hamster ovary cell-derived recombinant human acid alpha-glucosidase in infantile-onset Pompe disease. J Pediatr. Jul. 2006;149(1):89-97. [pmid: 16860134].
31 Kobayashi H, Shimada Y, Ikegami M, et al. Prognostic factors for the late onset Pompe disease with enzyme replacement therapy: from our experience of 4 cases including an autopsy case. Mol Genet Metab. May. 2010;100(1):14-9. [pmid: 20202878].
32 Koeberl DD, Kishnani PS. Pompe’s disease: Enzyme replacement therapy. Drugs of the Future. 2007;32(12):1067-70.
33 Koeberl DD, Kishnani PS, Chen YT. Glycogen storage disease types I and II: treatment updates. J Inherit Metab Dis. Apr. 2007;30(2):159-64. [pmid: 17308886].
34 Levine JC, Kishnani PS, Chen YT, et al. Cardiac remodeling after enzyme replacement therapy with acid alpha-glucosidase for infants with Pompe disease. Pediatr Cardiol. Nov. 2008;29(6):1033-42. [pmid: 18661169].
35 McDowell R, Li JS, Benjamin DK Jr, et al. Arrhythmias in patients receiving enzyme replacement therapy for infantile Pompe disease. Genet Med. Oct. 2008;10(10):758-62. [pmid: 18813140].
36 McVie-Wylie AJ, Lee KL, Qiu H, et al. Biochemical and pharmacological characterization of different recombinant acid alpha-glucosidase preparations evaluated for the treatment of Pompe disease. Mol Genet Metab. Aug. 2008;94(4):448-55. [pmid: 18538603].
37 Mellies U, Lofaso F. Pompe disease: a neuromuscular disease with respiratory muscle involvement. Respir Med. Apr. 2009;103(4):477-84. [pmid: 19131232].
38 Merk T, Wibmer T, Schumann C, et al. Glycogen storage disease type II (Pompe disease)–influence of enzyme replacement therapy in adults. Eur J Neurol. Feb. 2009;16(2):274-7. [pmid: 19138339].
39 Nicolino M, Byrne B, Wraith JE, et al. Clinical outcomes after long-term treatment with alglucosidase alfa in infants and children with advanced Pompe disease. Genet Med. Mar. 2009;11(3):210-9. [pmid: 19287243].
40 Orlikowski D, Pellegrini N, Prigent H, et al. Recombinant human acid alpha-glucosidase (rhGAA) in adult patients with severe respiratory failure due to Pompe disease. Neuromuscul Disord. Jul. 2011;21(7):477-82. [pmid: 21550241].
41 Papadimas GK, Spengos K, Konstantinopoulou A, et al. Adult Pompe disease: clinical manifestations and outcome of the first Greek patients receiving enzyme replacement therapy. Clin Neurol Neurosurg. May. 2011;113(4):303-7. [pmid: 21216089].
42 Parenti G, Andria G. Pompe disease: from new views on pathophysiology to innovative therapeutic strategies. Curr Pharm Biotechnol. Jun. 2011;12(6):902-15. [pmid: 21235442].
43 Pascual SI. Phenotype variations in early onset Pompe disease: diagnosis and treatment results with Myozyme. Adv Exp Med Biol. 2009;652:39-46. [pmid: 20225018].
44 Pascual-Pascual SI, Rubio P, Albajara L, et al. Sudden deterioration in nonclassical infantile-onset Pompe disease responding to alglucosidase alfa infusion therapy: a case report. J Inherit Metab Dis. Dec. 2006;29(6):763. [pmid: 17041744].
45 Pastores GM, Hughes DA. Enzyme-replacement therapy for Pompe disease. Pediatric Health. 2009;3(1):41-9.
46 Pereira SJ, Berditchevisky CR, Marie SK. Report of the first Brazilian infantile Pompe disease patient to be treated with recombinant human acid alpha-glucosidase. J Pediatr (Rio J). May–Jun. 2008;84(3):272-5. [pmid: 18535739].
47 Ravaglia S, Danesino C, Pichiecchio A, et al. Enzyme replacement therapy in severe adult-onset glycogen storage disease type II. Adv Ther. Aug. 2008;25(8):820-9. [pmid: 18704279].
48 Regnery C, Kornblum C, Hanisch F, et al. 36 months observational clinical study of 38 adult Pompe disease patients under alglucosidase alfa enzyme replacement therapy. J Inherit Metab Dis. 2012. Jan. 31. [pmid: 22290025].
49 Richard E, Douillard-Guilloux G, Caillaud C. New insights into therapeutic options for Pompe disease. IUBMB Life. Nov. 2011;63(11):979-86. [pmid: 22002928].
50 Schoser B, Hill V, Raben N. Therapeutic approaches in glycogen storage disease type II/Pompe Disease. Neurotherapeutics. Oct. 2008;5(4):569-78. [pmid: 19019308].
51 Spiridigliozzi GA, Heller JH, Case LE, et al. Early cognitive development in children with infantile Pompe disease. Mol Genet Metab. Mar. 2012;105(3):428-32. [pmid: 22217428].
52 Spiridigliozzi GA, Heller JH, Kishnani PS. Cognitive and adaptive functioning of children with infantile Pompe disease treated with enzyme replacement therapy: long-term follow-up. Am J Med Genet C Semin Med Genet. Feb. 15. 2012;160(1):22-9. [pmid: 22253038].
53 Strothotte S, Strigl-Pill N, Grunert B, et al. Enzyme replacement therapy with alglucosidase alfa in 44 patients with late-onset glycogen storage disease type 2: 12-month results of an observational clinical trial. J Neurol. Jan. 2010;257(1):91-7. [pmid: 19649685].
54 Sun B, Bird A, Young SP, et al. Enhanced response to enzyme replacement therapy in Pompe disease after the induction of immune tolerance. Am J Hum Genet. Nov. 2007;81(5):1042-9. [pmid: 17924344].
55 Terzis G, Dimopoulos F, Papadimas GK, et al. Effect of aerobic and resistance exercise training on late-onset Pompe disease patients receiving enzyme replacement therapy. Molecular Genetics and Metabolism. 2011;104(3):279-83. [pmid: 21640624].
56 Thurberg BL, Lynch Maloney C, Vaccaro C, et al. Characterization of pre- and post-treatment pathology after enzyme replacement therapy for Pompe disease. Lab Invest. Dec. 2006;86(12):1208-20. [pmid: 17075580].
57 Tinkle BT, Leslie N. Glycogen Storage Disease Type II (Pompe Disease). 1993. [pmid: 20301438].
58 van Capelle CI, van der Beek NAME, Hagemans MLC, et al. Effect of enzyme therapy in juvenile patients with Pompe disease: A three-year open-label study. Neuromuscular Disorders. 2010;20(12):775-82. [pmid: 20817528].
59 van der Ploeg AT. Where do we stand in enzyme replacement therapy in Pompe’s disease?. Neuromuscular Disorders. 2010;20(12):773-4. [pmid: 21094929].
60 van der Ploeg AT, Clemens PR, Corzo D, et al. A randomized study of alglucosidase alfa in late-onset Pompe’s disease. N Engl J Med. Apr. 15. 2010;362(15):1396-406. [pmid: 20393176].
61 van der Ploeg AT, Reuser AJ. Pompe’s disease. Lancet. Oct. 11. 2008;372(9646):1342-53. [pmid: 18929906].
62 Vielhaber S, Brejova A, Debska-Vielhaber G, et al. 24-months results in two adults with Pompe disease on enzyme replacement therapy. Clin Neurol Neurosurg. Jun. 2011;113(5):350-7. [pmid: 21477922].
63 Yang CC, Chien YH, Lee NC, et al. Rapid progressive course of later-onset Pompe disease in Chinese patients. Mol Genet Metab. Nov. 2011;104(3):284-8. [pmid: 21757382].
64 Yanovitch TL, Casey R, Banugaria SG, et al. Improvement of bilateral ptosis on higher dose enzyme replacement therapy in Pompe disease. J Neuroophthalmol. Jun. 2010;30(2):165-6. [pmid: 20404746].