# Summaries of Unpublished Studies

Appendix Table D1 Unpublished Studies From Manufacturer’s Scientific Information Packet and Current Registered Clinical Trials