# Summaries of Published Registry Studies

Appendix Table C1 Published Registry Study of ERT for Fabry Disease

Appendix Table C2 Published Registry Studies of ERT for Gaucher Disease

Appendix Table C3 Published Registry Studies of ERT for MPS II

Appendix Table C4 Published Registry Studies of ERT for MPS VI