# Appendix Data Abstraction Tables

Clinical Trials of Enzyme Replacement Therapy for Lysosomal Storage Diseases