# Electronic Database Search Strategies

## Search 1 -

“Mucopolysaccharidosis I”[Mesh] OR (“mucopolysaccharidosis” AND “type 1”) OR “mucopolysaccharidosis I” OR “mucopolysaccharidosis-I” OR “MPS I” OR “Hurler disease” OR “hurler syndrome”

AND

laronidase OR aldurazyme

AND

English language, humans

Results in [underlined: PubMed] = 36

29 additional studies identified using the search in [underlined: EMBASE] = 15 appeared to be unique and possibly relevant

[underlined: Cochrane] search found 4 trials – all are in the database.

## Search 2 –

“Mucopolysaccharidosis II”[Mesh] OR (mucopolysaccharidosis AND “type II”) OR “mucopolysaccharidosis II” OR “mucopolysaccharidosis-II” OR “MPS II” OR “Hunter disease” OR “hunter syndrome”

AND

“idursulfase” [Supplementary Concept] OR idursulfase OR elaprase

AND

English language, humans

Results in [underlined: PubMed] = 34

67 additional studies identified using the search in [underlined: EMBASE] = 3 appeared to be unique and possibly relevant

[underlined: Cochrane] search found 1 protocol and 2 trials that were unique and added to the database.

## Search 3 –

“Mucopolysaccharidosis VI”[Mesh] OR (mucopolysaccharidosis AND “type VI”) OR “mucopolysaccharidosis VI” OR “mucopolysaccharidosis-VI” OR “MPS VI” OR “maroteaux-lamy syndrome”

AND

“galsulfase” [Supplementary Concept] OR galsulfase OR naglazyme

AND

English language, humans

Results in [underlined: PubMed] =21

24 additional studies identified using the search in [underlined: EMBASE] = 6 appeared to be unique and possibly relevant

[underlined: Cochrane] search found 1 new technology assessment which was added. Everything else was already there.

## Search 4 –

“Fabry Disease”[Mesh] OR “fabry disease” OR “alpha-Galactosidase A Deficiency”

AND

“agalsidase beta” [Supplementary Concept] OR “agalsidase beta” OR fabrazyme

AND

English language, humans

Results in [underlined: PubMed] =132

130 studies identified using the search in [underlined: EMBASE] = 13 appeared to be unique and possibly relevant

[underlined: Cochrane] search found 2 additional trials which were added.

## Search 5 -

“Gaucher Disease”[Mesh] OR “gaucher disease” OR “gaucher’s disease”

AND

((“alglucerase” [Supplementary Concept]) OR “imiglucerase” [Supplementary Concept]) OR “Velaglucerase alfa, human” [Supplementary Concept] OR alglucerase OR ceredase OR imiglucerase OR cerezyme OR velaglucerase OR “miglustat” [Supplementary Concept] OR miglustat OR zavesca

AND

(“type 1” OR “type I”) OR various study types (RCT, meta-analysis, comparative study)

AND

English language, humans

Results in [underlined: PubMed] =222

65 clinical studies identified in [underlined: EMBASE] = 4 appeared to be unique and possibly relevant

[underlined: Cochrane] search found 4 additional articles which were added.

## Search 6 –

“Glycogen Storage Disease Type II”[Mesh] OR (“glycogen storage disease” AND (“type II” OR “type 2”)) OR “pompe disease” OR “pompe’s disease”

AND

“GAA protein, human” [Supplementary Concept] OR “alglucosidase alfa” OR myozyme

AND

English language, humans

Results in [underlined: PubMed] =99

41 clinical studies identified in [underlined: EMBASE] = 8 appeared to be unique and possibly relevant

[underlined: Cochrane] search found 2 trials – only 1 unique one – a meeting abstract – was added.