# Summary and Implications

The present technology brief assessed the current state of science regarding noninvasive diagnostic techniques for the detection of skin cancers, particularly BCC, SCC, and melanoma. In addition, we sought to assess the clinical application of these modalities and their diffusion across specialty/subspecialty groups.

Based on these objectives, we found that the use of photography to capture suspicious skin lesions of the entire body for monitoring purposes is commonly used in dermatology practices, but not typically in a primary care setting. Photographic surveillance is recommended for patients at high risk of skin cancer, based on family history, history of dysplastic nevi, or history of prior malignant lesions.48,49 However, the age of onset and frequency at which it should be performed is unclear. The affordability and adaptability of digital imaging permit the increased ease of electronic image storage and allow for side-by-side comparisons at future visits. The evolution of computerized imaging systems has also enhanced the ability to convey these lesions from patients to providers and across provider types. The available data are limited on the role of photography in changing clinical outcomes, including confirmation that baseline photographs in specialty clinics improve the detection of melanoma, resulting in detection of earlier stage lesions, or recurrent lesions. While there are some studies, principally from Australia, about the impact of photography in primary care settings, no similar studies have been conducted in the United States.

In addition, we found that approximately half of recently surveyed U.S. dermatologists use some form of dermoscopy (polarized light noncontact, polarized light contact, and nonpolarized light immersion).57 Except for anecdotal information describing the use of dermoscope in primary care settings, it is not routinely used in non-dermatologist settings. A handheld dermoscope can provide at least a 10-fold magnification of skin lesions and aid in the assessment of pigmented or papulosquamous lesion morphology. Almost all the primary studies on dermoscopy were non-randomized. The non-randomized studies tended to focus on features of dermoscopic image that would be of diagnostic interest. We did not identify any controlled studies examining the use of dermoscopy to increase the detection rate of early stage melanoma. The primary studies that reported patient outcomes largely focused on number of new lesions and how lesions had evolved. No study reported on how the addition of dermoscopy affected survival from melanoma.

One RCT did compare dermoscopic evaluation and naked-eye examination in primary care physicians in Italy and Spain and inferred the effect of the addition of dermoscopy on the likelihood that a primary care physician would fail to refer a patient with suspicious skin lesions for a second expert opinion. A second RCT of patients in Italy examined the downstream effect on the number of skin lesion excised for diagnostic verification with the addition of dermoscopy in a pigmented lesion clinic. Whether the findings from the two European RCTs are applicable to the U.S. population and whether they could be further translated into actual detection of different forms of skin cancer and/or affecting survival in afflicted patients are uncertain as the practice patterns are different between the two countries and no trials that examined the effects of the addition of dermoscopy to naked eye examinations reported on these outcomes. Based on the abstracts reviewed, we surmise that the actual conduct of dermoscopy as practiced in a U.S. dermatology setting must be quite heterogeneous owing to the different available algorithms, devices, training, and practitioner's experience and belief about the benefits of this technology. Any new trials in the United States investigating the benefit of dermoscopy compared with naked eye examination in affecting health outcomes will have to take into account this heterogeneity.

Similarly, dermatologists are the primary users of confocal scanning laser microscopy (CSLM), which aids in the evaluation of skin lesions by providing high resolution skin tissue images that are similar to histopathological images. The high cost of confocal microscopes is an obstacle to the widespread diffusion of this technique. There are no trials comparing CSLM with the use of other diagnostic techniques (such as clinical examination or dermoscopy). Reported outcomes in cohort studies mainly focused on lesion characterizations by CSLM and its test accuracy.

While numerous other modalities, including high frequency ultrasound/Doppler and PDD, are available, their use is still limited in clinical practice, and several, such as multiphoton microscopy, bio-electrical impedance, OCT, tape stripping, multispectral imaging and fully automated computer-based analysis, and thermography, are considered investigational. There are virtually no trials that compare their accuracy and patient outcomes with conventional histological determination. Test accuracy of many of these investigational modalities has not been adequately assessed. It is unclear whether these modalities perform better in diagnosing certain types of skin cancer or among subgroups of patients, such as specific ethnic/racial groups or history of prior cancer (skin or other site). In addition, evidence supporting the use of these investigational modalities to replace further diagnostic evaluation is lacking. Little to no data was available to assess the safety and potential harms related to the use of these technologies. Research on the use, diffusion, and training of different modalities has yet to be conducted. In summary, for most of these technologies, the abstracts we identified addressed their technical efficacy and/ or diagnostic accuracy efficacy, leaving unanswered questions enumerated above.