# References

1 American Cancer Society. Cancer Facts & Figures. 2009. Atlanta. American Cancer Society. Available at: http://www.cancer.org/Research/CancerFactsFigures/cancer-facts-figures-2009. August 24, 2011.
2 Perkins JL, Liu Y, Mitby PA, et al. Nonmelanoma skin cancer in survivors of childhood and adolescent cancer: a report from the childhood cancer survivor study. J Clin Oncol. 2005;23(16):3733-3741. [pmid: 15923570].
3 Rosenberg CA, Greenland P, Khandekar J, et al. Association of nonmelanoma skin cancer with second malignancy. Cancer. 2004;100(1):130-138. [pmid: 14692033].
4 Hong WK, Bast RC, Hait WN, et al. Holland-Frei Cancer Medicine. 8th Edition. Shelton, CT. People's Medical Publishing House USA. 2010.
5 Linos E, Swetter SM, Cockburn MG, et al. Increasing burden of melanoma in the United States. J Invest Dermatol. 2009;129(7):1666-1674. [pmid: 19131946].
6 Hu S, Parmet Y, Allen G, et al. Disparity in melanoma: a trend analysis of melanoma incidence and stage at diagnosis among whites, Hispanics, and blacks in Florida. Arch Dermatol. 2009;145(12):1369-1374. [pmid: 20026844].
7 Gloster HM Jr, Brodland DG. The epidemiology of skin cancer. Dermatol Surg. 1996;22(3):217-226. [pmid: 8599733].
8 Tsao H, Atkins MB, Sober AJ. Management of cutaneous melanoma. N Engl J Med. 2004;351(10):998-1012. [pmid: 15342808].
9 Garbe C, Peris K, Hauschild A, et al. Diagnosis and treatment of melanoma: European consensus-based interdisciplinary guideline. Eur J Cancer. 2010;46(2):270-283. [pmid: 19959353].
10 Australian Cancer Network Melanoma Guidelines Revision Working Party. Clinical Practice Guidelines for the Management of Melanoma in Australia and New Zealand. 2008. Cancer Council Australia and Australian Cancer Network, Sydney and New Zealand Guidelines Group.
11 Screening for skin cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009;150(3):188-193. [pmid: 19189908].
12 From L, Marret L, Rosen C, et al. Screening for Skin Cancer. June. 19. 2007. Cancer Care Ontario.
13 National Guideline Clearinghouse (NGC). Guideline synthesis: Screening and prevention of skin cancer. National Guideline Clearinghouse (NGC). [guideline.gov]. Available at: http://www.guideline.gov. November 1, 2009.
14 Goodson AG, Grossman D. Strategies for early melanoma detection: Approaches to the patient with nevi. [Review] [159 refs]. Journal of the American Academy of Dermatology. 2009;60(5):719-735. [pmid: 19389517].
15 Terushkin V, Halpern AC. Melanoma early detection. Hematol Oncol Clin North Am. 2009;23(3):481-500. viii. [pmid: 19464598].
16 Marghoob AA, Swindle LD, Moricz CZ, et al. Instruments and new technologies for the in vivo diagnosis of melanoma. J Am Acad Dermatol. 2003;49(5):777-797. [pmid: 14576657].
17 Thornbury JR, Fryback DG. Technology assessment—an American view. Eur J Radiol. 1992;14(2):147-156. [pmid: 1563415].
18 Improving Outcomes for People with Skin Tumours including Melanoma (update): The Management of Low-risk Basal Cell Carcinomas in the Community. May. 1. 2010. Guidance on Cancer Services, the National Collaborating Centre for Cancer (NICE).
19 Rice ZP, Weiss FJ, DeLong LK, et al. Utilization and rationale for the implementation of total body (digital) photography as an adjunct screening measure for melanoma. Melanoma Research. 2010;20(5):417-421. [pmid: 20729763].
20 Shriner DL, Wagner RF Jr. Photographic utilization in dermatology clinics in the United States: a survey of university-based dermatology residency programs. Journal of the American Academy of Dermatology. 1992;27(4):565-567. [pmid: 1401308].
21 Terushkin V, Oliveria SA, Marghoob AA, et al. Use of and beliefs about total body photography and dermatoscopy among US dermatology training programs: an update. Journal of the American Academy of Dermatology. 2010;62(5):794-803. [pmid: 20223561].
22 Rigel DS, Russak J, Friedman R. The evolution of melanoma diagnosis: 25 years beyond the ABCDs. CA Cancer J Clin. 2010;60(5):301-316. [pmid: 20671054].
23 Esmaeili A, Scope A, Halpern AC, et al. Imaging techniques for the in vivo diagnosis of melanoma. [Review] [50 refs]. Seminars in Cutaneous Medicine & Surgery. 2008;27(1):2-10. [pmid: 18486018].
24 Halpern AC, Marghoob AA, Bialoglow TW, et al. Standardized positioning of patients (poses) for whole body cutaneous photography. Journal of the American Academy of Dermatology. 2003;49(4):593-598. [pmid: 14512902].
25 Shriner DL, Wagner RF Jr, Glowczwski JR. Photography for the early diagnosis of malignant melanoma in patients with atypical moles. [Review] [22 refs]. Cutis. 1992;50(5):358-362. [pmid: 1468257].
26 Oakley AM, Reeves F, Bennett J, et al. Diagnostic value of written referral and/or images for skin lesions. Journal of Telemedicine & Telecare. 2006;12(3):151-158. [pmid: 16638237].
27 Harrison SL, Buettner PG, MacLennan R, et al. How good are parents at assessing melanocytic nevi on their children? A study comparing parental counts, dermatologist counts, and counts obtained from photographs. American Journal of Epidemiology. 2002;155(12):1128-1136. [pmid: 12048227].
28 Chiu V, Won E, Malik M, et al. The use of mole-mapping diagrams to increase skin self-examination accuracy. Journal of the American Academy of Dermatology. 2006;55(2):245-250. [pmid: 16844506].
29 Phelan DL, Oliveria SA, Halpern AC. Patient experiences with photo books in monthly skin self-examinations. Dermatology Nursing. 2005;17(2):109-114. [pmid: 15916185].
30 Weinstock MA, Nguyen FQ, Martin RA. Enhancing skin self-examination with imaging: evaluation of a mole-mapping program. Journal of Cutaneous Medicine & Surgery. 2004;8(1):1-5. [pmid: 15688095].
31 Banky JP, Kelly JW, English DR, et al. Incidence of new and changed nevi and melanomas detected using baseline images and dermoscopy in patients at high risk for melanoma. Archives of Dermatology. 2005;141(8):998-1006. [pmid: 16103329].
32 Drugge RJ, Nguyen C, Drugge ED, et al. Melanoma screening with serial whole body photographic change detection using Melanoscan technology. Dermatology Online Journal. 2009;15(6):1. [pmid: 19723475].
33 Feit NE, Dusza SW, Marghoob AA. Melanomas detected with the aid of total cutaneous photography. British Journal of Dermatology. 2004;150(4):706-714. [pmid: 15099367].
34 Wang SQ, Kopf AW, Koenig K, et al. Detection of melanomas in patients followed up with total cutaneous examinations, total cutaneous photography, and dermoscopy. Journal of the American Academy of Dermatology. 2004;50(1):15-20. [pmid: 14699359].
35 Risser J, Pressley Z, Veledar E, et al. The impact of total body photography on biopsy rate in patients from a pigmented lesion clinic. Journal of the American Academy of Dermatology. 2007;57(3):428-434. [pmid: 17624623].
36 Halpern AC, Lieb JA. Early melanoma diagnosis: a success story that leaves room for improvement. [Review] [84 refs]. Current Opinion in Oncology. 2007;19(2):109-115. [pmid: 17272982].
37 Psaty EL, Halpern AC. Current and emerging technologies in melanoma diagnosis: the state of the art. [Review] [109 refs]. Clinics in Dermatology. 2009;27(1):35-45. [pmid: 19095152].
38 Rhodes AR. Intervention strategy to prevent lethal cutaneous melanoma: use of dermatologic photography to aid surveillance of high-risk persons. [Review] [46 refs]. Journal of the American Academy of Dermatology. 1998;39(2:Pt 1):t-7.
39 Patel JK, Konda S, Perez OA, et al. Newer technologies/techniques and tools in the diagnosis of melanoma. [Review] [172 refs]. European Journal of Dermatology. 2008;18(6):617-631. [pmid: 18955194].
40 Drugge RJ, Nguyen C, Gliga L, et al. Clinical pathway for melanoma detection using comprehensive cutaneous analysis with Melanoscan. Dermatology Online Journal. 2010;16(8):1. [pmid: 20804678].
41 Zhou Y, Smith M, Smith L, et al. Using 3D differential forms to characterize a pigmented lesion in vivo. Skin Research & Technology. 2010;16(1):77-84. [pmid: 20384886].
42 Christensen JH, Soerensen MB, Linghui Z, et al. Pre-diagnostic digital imaging prediction model to discriminate between malignant melanoma and benign pigmented skin lesion. Skin Research & Technology. 2010;16(1):98-108. [pmid: 20384888].
43 Green WH, Wang SQ, Cognetta AB Jr. Total-body cutaneous examination, total-body photography, and dermoscopy in the care of a patient with xeroderma pigmentosum and multiple melanomas. Archives of Dermatology. 2009;145(8):910-915. [pmid: 19687422].
44 Malvehy J, Puig S. Follow-up of melanocytic skin lesions with digital total-body photography and digital dermoscopy: a two-step method. [Review] [41 refs]. Clinics in Dermatology. 2002;20(3):297-304. [pmid: 12074871].
45 Rademaker M, Oakley A. Digital monitoring by whole body photography and sequential digital dermoscopy detects thinner melanomas. Journal of Primary Health Care. 2010;2(4):268-272. [pmid: 21125066].
46 Massone C, Wurm EM, Soyer HP. Teledermatology. [Review] [50 refs]. Giornale Italiano di Dermatologia e Venereologia. 2008;143(3):213-218. [pmid: 18833064].
47 Harrison PV, Kirby B, Dickinson Y, et al. Teledermatology—high technology or not?. Journal of Telemedicine & Telecare. 1998;4(Suppl-2).
48 BlueCross BlueShield of North Carolina. Evidence Based Guideline Total Body Photography. Available at: http://www.bcbsnc.com/assets/services/public/pdfs/medicalpolicy/total_body_photography.pdf. 2009. August 23, 2011.
49 Halpern AC. Total body skin imaging as an aid to melanoma detection. [Review] [29 refs]. Seminars in Cutaneous Medicine & Surgery. 2003;22(1):2-8. [pmid: 12773009].
50 Campos-do-Carmo G, Ramos-e-Silva. Dermoscopy: basic concepts. [Review] [22 refs]. International Journal of Dermatology. 2008;47(7):712-719. [pmid: 18613881].
51 venuto-Andrade C, Dusza SW, Agero AL, et al. Differences between polarized light dermoscopy and immersion contact dermoscopy for the evaluation of skin lesions. Arch Dermatol. 2007;143(3):329-338. [pmid: 17372097].
52 Bassoli S, Seidenari S. Benefits of polarized versus nonpolarized dermoscopy. Expert Review of Dermatology. 2010.
53 Marchionda PJ, Krause LK, Jensen JD, et al. A North American perspective on dermoscopy: benefits, limitations, and grey zones. [Review] [108 refs]. Giornale Italiano di Dermatologia e Venereologia. 2010;145(1):89-97. [pmid: 20197748].
54 Wang SQ, Dusza SW, Scope A, et al. Differences in dermoscopic images from nonpolarized dermoscope and polarized dermoscope influence the diagnostic accuracy and confidence level: a pilot study. Dermatologic Surgery. 2008;34(10):1389-1395. [pmid: 18637816].
55 Argenziano G, Puig S, Zalaudek I, et al. Dermoscopy improves accuracy of primary care physicians to triage lesions suggestive of skin cancer. Journal of Clinical Oncology. 2006;24(12):1877-1882. [pmid: 16622262].
56 Carli P, De GV, Chiarugi A, et al. Addition of dermoscopy to conventional naked-eye examination in melanoma screening: a randomized study. Journal of the American Academy of Dermatology. 2004;50(5):683-689. [pmid: 15097950].
57 Noor O, Nanda A, Rao BK. A dermoscopy survey to assess who is using it and why it is or is not being used. Int J Dermatol. 2009;48(9):951-952. [pmid: 19702978].
58 Massone C, Di SA, Soyer HP. Dermoscopy for skin cancer detection. [Review] [71 refs]. Current Opinion in Oncology. 2005;17(2):147-153. [pmid: 15725920].
59 Zalaudek I, Kittler H, Marghoob AA, et al. Time required for a complete skin examination with and without dermoscopy: a prospective, randomized multicenter study. Archives of Dermatology. 2008;144(4):509-513. [pmid: 18427045].
60 Franz H, Frank R, Rytter M, et al. Allergic contact dermatitis due to cedarwood oil after dermatoscopy. Contact Dermatitis. 1998;38(3):182-183. [pmid: 9536426].
61 Salsano E, Pareyson D, Politi LS. Tonic pupil following the use of dermatoscope. Acta Neurologica Taiwanica. 2009;18(2):148-150. [pmid: 19673371].
62 Stauffer F, Kittler H, Forstinger C, et al. The dermatoscope: a potential source of nosocomial infection?. Melanoma Research. 2001;11(2):153-156. [pmid: 11333125].
63 Hausermann P, Widmer A, Itin P. Dermatoscope as vector for transmissible diseases - no apparent risk of nosocomial infections in outpatients. Dermatology. 2006;212(1):27-30. [pmid: 16319470].
64 Kelly SC, Purcell SM. Prevention of nosocomial infection during dermoscopy?. Dermatologic Surgery. 2006;32(4):552-555. [pmid: 16681664].
65 Binder M, Kittler H, Pehamberger H, et al. Possible hazard to patients from immersion oil used for epiluminescence microscopy. Journal of the American Academy of Dermatology. 1999;40(3):499. [pmid: 10071334].
66 Marghoob AA, Swindle LD, Moricz CZ, et al. Instruments and new technologies for the in vivo diagnosis of melanoma. [Review] [160 refs]. Journal of the American Academy of Dermatology. 798. 49(5):777-797. [pmid: 14576657].
67 Braun RP, Rabinovitz HS, Oliviero M, et al. Dermoscopy of pigmented skin lesions. [Review] [98 refs]. Journal of the American Academy of Dermatology. 2005;52(1):109-121. [pmid: 15627088].
68 Engasser HC, Warshaw EM. Dermatoscopy use by US dermatologists: a cross-sectional survey. J Am Acad Dermatol. 2010;63(3):412-9. 419. [pmid: 20619490].
69 Haenssle HA, Korpas B, Hansen-Hagge C, et al. Selection of patients for long-term surveillance with digital dermoscopy by assessment of melanoma risk factors. Archives of Dermatology. 2010;146(3):257-264. [pmid: 20231495].
70 De GV, Trez E, Salvini C, et al. Dermoscopy in black people. British Journal of Dermatology. 2006;155(4):695-699. [pmid: 16965417].
71 Chen SC, Pennie ML, Kolm P, et al. Diagnosing and managing cutaneous pigmented lesions: primary care physicians versus dermatologists. J Gen Intern Med. 2006;21(7):678-682. [pmid: 16808765].
72 Westerhoff K, McCarthy WH, Menzies SW. Increase in the sensitivity for melanoma diagnosis by primary care physicians using skin surface microscopy. British Journal of Dermatology. 2000;143(5):1016-1020. [pmid: 11069512].
73 Menzies SW, Emery J, Staples M, et al. Impact of dermoscopy and short-term sequential digital dermoscopy imaging for the management of pigmented lesions in primary care: a sequential intervention trial. British Journal of Dermatology. 2009;161(6):1270-1277. [pmid: 19747359].
74 Goulart JM, Malvehy J, Puig S, et al. Dermoscopy in skin self-examination: A useful tool for select patients. Archives of Dermatology. 2011;147(1):53-58. [pmid: 21242394].
75 Rajpara SM, Botello AP, Townend J, et al. Systematic review of dermoscopy and digital dermoscopy/artificial intelligence for the diagnosis of melanoma. [Review] [95 refs]. British Journal of Dermatology. 2009;161(3):591-604. [pmid: 19302072].
76 Vestergaard ME, Macaskill P, Holt PE, et al. Dermoscopy compared with naked eye examination for the diagnosis of primary melanoma: a meta-analysis of studies performed in a clinical setting. British Journal of Dermatology. 2008;159(3):669-676. [pmid: 18616769].
77 Kittler H, Pehamberger H, Wolff K, et al. Diagnostic accuracy of dermoscopy. [Review] [41 refs]. Lancet Oncology. 2002;3(3):159-165.
78 Bafounta ML, Beauchet A, Aegerter P, et al. Is dermoscopy (epiluminescence microscopy) useful for the diagnosis of melanoma? Results of a meta-analysis using techniques adapted to the evaluation of diagnostic tests. Archives of Dermatology. 2001;137(10):1343-1350. [pmid: 11594860].
79 Hofmann-Wellenhof R, Wurm EM, hlgrimm-Siess V, et al. Reflectance confocal microscopy--state-of-art and research overview. Seminars in Cutaneous Medicine & Surgery. 2009;28(3):172-179. [pmid: 19782941].
80 Gonzalez S. Confocal reflectance microscopy in dermatology: promise and reality of non-invasive diagnosis and monitoring. Actas Dermo-Sifiliograficas. 2009;100(Suppl-69).
81 Branzan AL, Landthaler M, Szeimies RM. In vivo confocal scanning laser microscopy in dermatology. [Review] [57 refs]. Lasers in Medical Science. 2007;22(2):73-82. [pmid: 17115235].
82 Scope A, venuto-Andrade C, Agero AL, et al. In vivo reflectance confocal microscopy imaging of melanocytic skin lesions: consensus terminology glossary and illustrative images. Journal of the American Academy of Dermatology. 2007;57(4):644-658. [pmid: 17630045].
83 Guitera P, Pellacani G, Longo C, et al. In vivo reflectance confocal microscopy enhances secondary evaluation of melanocytic lesions. Journal of Investigative Dermatology. 2009;129(1):131-138. [pmid: 18633444].
84 Guitera P, Pellacani G, Crotty KA, et al. The impact of in vivo reflectance confocal microscopy on the diagnostic accuracy of lentigo maligna and equivocal pigmented and nonpigmented macules of the face. Journal of Investigative Dermatology. 2010;130(8):2080-2091. [pmid: 20393481].
85 Pellacani G, Guitera P, Longo C, et al. The impact of in vivo reflectance confocal microscopy for the diagnostic accuracy of melanoma and equivocal melanocytic lesions. Journal of Investigative Dermatology. 2007;127(12):2759-2765. [pmid: 17657243].
86 Segura S, Puig S, Carrera C, et al. Development of a two-step method for the diagnosis of melanoma by reflectance confocal microscopy. Journal of the American Academy of Dermatology. 2009;61(2):216-229. [pmid: 19406506].
87 Rajadhyaksha M. Confocal microscopy of skin cancers: translational advances toward clinical utility. Conference Proceedings: 2009;Annual:International-3.
88 Nehal KS, Gareau D, Rajadhyaksha M. Skin imaging with reflectance confocal microscopy. [Review] [51 refs]. Seminars in Cutaneous Medicine & Surgery. 2008;27(1):37-43. [pmid: 18486023].
89 Zmudzinska M, Czarnecka-Operacz M, Silny W. Principles of dermatologic ultrasound diagnostics. [Review] [22 refs]. Acta Dermatovenerologica Croatica. 2008;16(3):126-129. [pmid: 18812060].
90 Guitera P, Li LX, Crotty K, et al. Melanoma histological Breslow thickness predicted by 75-MHz ultrasonography. British Journal of Dermatology. 2008;159(2):364-369. [pmid: 18565186].
91 Vilana R, Puig S, Sanchez M, et al. Preoperative assessment of cutaneous melanoma thickness using 10-MHz sonography. AJR Am J Roentgenol. 2009;193(3):639-643. [pmid: 19696275].
92 Pellacani G, Seidenari S. Preoperative melanoma thickness determination by 20-MHz sonography and digital videomicroscopy in combination. Archives of Dermatology. 2003;139(3):293-298. [pmid: 12622620].
93 Serrone L, Solivetti FM, Thorel MF, et al. High frequency ultrasound in the preoperative staging of primary melanoma: a statistical analysis. Melanoma Research. 2002;12(3):287-290. [pmid: 12140386].
94 Weichenthal M, Mohr P, Breitbart EW. The velocity of ultrasound in human primary melanoma tissue - implications for the clinical use of high resolution sonography. BMC Dermatology. 2001;1:1. [pmid: 11445001].
95 Schmid-Wendtner MH, Burgdorf W. Ultrasound scanning in dermatology. [Review] [30 refs]. Archives of Dermatology. 2005;141(2):217-224. [pmid: 15724019].
96 Dummer W, Blaheta HJ, Bastian BC, et al. Preoperative characterization of pigmented skin lesions by epiluminescence microscopy and high-frequency ultrasound. Archives of Dermatology. 1995;131(3):279-285. [pmid: 7887656].
97 Krahn G, Gottlober P, Sander C, et al. Dermatoscopy and high frequency sonography: two useful non-invasive methods to increase preoperative diagnostic accuracy in pigmented skin lesions. Pigment Cell Research. 1998;11(3):151-154. [pmid: 9730322].
98 Petrella LI, Pereira WC, Valle HA, et al. Study of superficial basal cell carcinomas and Bowen disease by qualitative and quantitative ultrasound biomicroscopy approach. Conference Proceedings: 2010;Annual:International. 6002.
99 Petrella LI, Valle HA, Issa PR, et al. Study of cutaneous cell carcinomas ex vivo using ultrasound biomicroscopic images. Skin Research & Technology. 2010;16(4):422-427. [pmid: 21039907].
100 Bajaj MS, Aalok L, Gupta V, et al. Ultrasound biomicroscopic appearances of eyelid lesions at 50 MHz. Journal of Clinical Ultrasound. 2007;35(8):424-429. [pmid: 17551943].
101 Desai TD, Desai AD, Horowitz DC, et al. The use of high-frequency ultrasound in the evaluation of superficial and nodular basal cell carcinomas. Dermatologic Surgery. 2007;33(10):1220-1227. [pmid: 17903155].
102 ll-Muller D, Maschke J. Ultrasonography in dermatology. [Review] [22 refs]. Journal der Deutschen Dermatologischen Gesellschaft. 2007;5(8):689-707. [pmid: 17659044].
103 Kennedy JC, Marcus SL, Pottier RH. Photodynamic therapy (PDT) and photodiagnosis (PD) using endogenous photosensitization induced by 5-aminolevulinic acid (ALA): mechanisms and clinical results. [Review] [53 refs]. Journal of Clinical Laser Medicine & Surgery. 1996;14(5):289-304. [pmid: 9612195].
104 Wortsman X, Wortsman J. Clinical usefulness of variable-frequency ultrasound in localized lesions of the skin. Journal of the American Academy of Dermatology. 2010;62(2):247-256. [pmid: 19962214].
105 Uhara H, Hayashi K, Koga H, et al. Multiple hypersonographic spots in basal cell carcinoma. Dermatologic Surgery. 2007;33(10):1215-1219. [pmid: 17903154].
106 Bessoud B, Lassau N, Koscielny S, et al. High-frequency sonography and color Doppler in the management of pigmented skin lesions. Ultrasound in Medicine & Biology. 2003;29(6):875-879. [pmid: 12837502].
107 Lassau N, Koscielny S, Avril MF, et al. Prognostic value of angiogenesis evaluated with high-frequency and color Doppler sonography for preoperative assessment of melanomas. AJR. American. 2002;(6):1547-1551. [pmid: 12034636].
108 Lassau N, Lamuraglia M, Koscielny S, et al. Prognostic value of angiogenesis evaluated with high-frequency and colour. Doppler sonography for preoperative assessment of primary cutaneous melanomas: correlation with recurrence after a 5 year follow-up period. Cancer Imaging. 2006;6:24-29. [pmid: 16644502].
109 Marcus SL, Sobel RS, Golub AL, et al. Photodynamic therapy (PDT) and photodiagnosis (PD) using endogenous photosensitization induced by 5-aminolevulinic acid (ALA): current clinical and development status. [Review] [23 refs]. Journal of Clinical Laser Medicine & Surgery. 1996;14(2):59-66. [pmid: 9484077].
110 Na R, Stender IM, Wulf HC. Can autofluorescence demarcate basal cell carcinoma from normal skin? A comparison with protoporphyrin IX fluorescence. Acta Dermato-Venereologica. 2001;81(4):246-249. [pmid: 11720169].
111 Fritsch C, Lang K, Neuse W, et al. Photodynamic diagnosis and therapy in dermatology. [Review] [74 refs]. Skin Pharmacology & Applied Skin Physiology. 1998;11(6):358-373. [pmid: 10343206].
112 Fotinos N, Campo MA, Popowycz F, et al. 5-Aminolevulinic acid derivatives in photomedicine: Characteristics, application and perspectives. [Review] [183 refs]. Photochemistry & Photobiology. 2006;82(4):994-1015. [pmid: 16542112].
113 Szeimies RM, Landthaler M. Photodynamic therapy and fluorescence diagnosis of skin cancers. [Review] [19 refs]. Recent Results in Cancer Research. 2002;160:240-245. [pmid: 12079219].
114 Fritsch C, Becker-Wegerich PM, Menke H, et al. Successful surgery of multiple recurrent basal cell carcinomas guided by photodynamic diagnosis. Aesthetic Plastic Surgery. 1997;21(6):437-439. [pmid: 9354609].
115 Lee CY, Kim KH, Kim YH. The efficacy of photodynamic diagnosis in defining the lateral border between a tumor and a tumor-free area during Mohs micrographic surgery. Dermatologic Surgery. 2010;36(11):1704-1710. [pmid: 20840493].
116 Wetzig T, Kendler M, Maschke J, et al. No clinical benefit of preoperative fluorescence diagnosis of basal cell carcinoma localized in the H-zone of the face. British Journal of Dermatology. 2010;162(6):1370-1376. [pmid: 20302577].
117 Vereecken P, Da Costa CM, Steels E, et al. Fluorescence diagnosis of face-located basal cell carcinomas: a new dermatological procedure which may help the surgeon. Acta Chirurgica Belgica. 2007;107(2):205-207. [pmid: 17515272].
118 Chwirot BW, Chwirot S, Redzinski J, et al. Detection of melanomas by digital imaging of spectrally resolved ultraviolet light-induced autofluorescence of human skin. European Journal of Cancer. 1998;34(11):1730-1734. [pmid: 9893661].
119 Allison RR, Sibata CH. Photodiagnosis for cutaneous malignancy: a brief clinical and technical review. [Review] [25 refs]. Photodiagnosis & Photodynamic Therapy. 2008;5(4):247-250. [pmid: 19356664].
120 Eichhorn R, Wessler G, Scholz M, et al. Early diagnosis of melanotic melanoma based on laser-induced melanin fluorescence. Journal of Biomedical Optics. 14(3):034033-034. Jun. [pmid: 19566326].
121 Taylor S, Westerhof W, Im S, et al. Noninvasive techniques for the evaluation of skin color. [Review] [32 refs]. Journal of the American Academy of Dermatology. 2006;54(5:Suppl 2). Suppl-90.
122 Lin SJ, Jee SH, Dong CY. Multiphoton microscopy: a new paradigm in dermatological imaging. [Review] [45 refs]. European Journal of Dermatology. 2007;17(5):361-366. [pmid: 17673377].
123 Paoli J, Smedh M, Ericson MB. Multiphoton laser scanning microscopy—a novel diagnostic method for superficial skin cancers. [Review] [45 refs]. Seminars in Cutaneous Medicine & Surgery. 2009;28(3):190-195. [pmid: 19782943].
124 Tsai TH, Jee SH, Dong CY, et al. Multiphoton microscopy in dermatological imaging. [Review] [51 refs]. Journal of Dermatological Science. 2009;56(1):1-8. [pmid: 19699614].
125 Aberg P, Nicander I, Holmgren U, et al. Assessment of skin lesions and skin cancer using simple electrical impedance indices. Skin Research & Technology. 2003;9(3):257-261. [pmid: 12877688].
126 Beetner DG, Kapoor S, Manjunath S, et al. Differentiation among basal cell carcinoma, benign lesions, and normal skin using electric impedance. IEEE Transactions on Biomedical Engineering. 2003;50(8):1020-1025. [pmid: 12892329].
127 Forsea AM, Carstea EM, Ghervase L, et al. Clinical application of optical coherence tomography for the imaging of nonmelanocytic cutaneous tumors: a pilot multimodal study. Journal of Medicine & Life. 2010;3(4):381-389. [pmid: 21254735].
128 Mogensen M, Thrane L, Joergensen TM, et al. Optical coherence tomography for imaging of skin and skin diseases. Seminars in Cutaneous Medicine & Surgery. 2009;28(3):196-202. [pmid: 19782944].
129 Olmedo JM, Warschaw KE, Schmitt JM, et al. Optical coherence tomography for the characterization of basal cell carcinoma in vivo: a pilot study. Journal of the American Academy of Dermatology. 2006;55(3):408-412. [pmid: 16908344].
130 De GV, Stante M, Massi D, et al. Possible histopathologic correlates of dermoscopic features in pigmented melanocytic lesions identified by means of optical coherence tomography. Experimental Dermatology. 2005;14(1):56-59. [pmid: 15660920].
131 Welzel J, Lankenau E, Birngruber R, et al. Optical coherence tomography of the human skin. Journal of the American Academy of Dermatology. 1997;37(6):958-963. [pmid: 9418764].
132 Berardi P, Arcangeli F. The tape stripping toluidine blue (TSTB) method in the diagnosis of malignant melanoma: an investigator-blind study. Melanoma Research. 1992;2(2):93-99. [pmid: 1643436].
133 Wachsman W, Morhenn V, Palmer T, et al. Noninvasive genomic detection of melanoma. Br J Dermatol. 2011;164(4):797-806. [pmid: 21294715].
134 Di CA. Thermography and the possibilities for its applications in clinical and experimental dermatology. [Review] [38 refs]. Clinics in Dermatology. 1995;13(4):329-336. [pmid: 8665441].
135 Cristofolini M, Perani B, Piscioli F, et al. Uselessness of thermography for diagnosis and follow-up of cutaneous malignant melanoma. Tumori. 1981;67(2):141-143. [pmid: 7256880].
136 Amalrich R, Altschuler C, Giraud D. Value of infrared thermography in the assessment of malignant melanoma of the skin. Ring EFJ, Phillips B, editors. Recent advances in medical thermology. New York/London. Plenum. 2010:623-629.
137 Monheit G, Cognetta AB, Ferris L, et al. The performance of MelaFind: a prospective multicenter study. Arch Dermatol. 2011;147(2):188-194. [pmid: 20956633].
138 Del Mar CB, Green AC. Aid to diagnosis of melanoma in primary medical care. BMJ. 1995;310(6978):492-495. [pmid: 7888887].
139 Hanrahan PF, Menzies SW, D'Este CA, et al. Participation of older males in a study on photography as an aid to early detection of melanoma. Australian & New Zealand Journal of Public Health. 2000;24(6):615-618. [pmid: 11215011].
140 Hanrahan PF, D'Este CA, Menzies SW, et al. A randomised trial of skin photography as an aid to screening skin lesions in older males. Journal of Medical Screening. 2002;9(3):128-132. [pmid: 12370325].
141 English DR, Burton RC, Del Mar CB, et al. Evaluation of aid to diagnosis of pigmented skin lesions in general practice: controlled trial randomised by practice. BMJ. 2003;327(7411):375. [pmid: 12919990].
142 Oliveria SA, Dusza SW, Phelan DL, et al. Patient adherence to skin self-examination. effect of nurse intervention with photographs. American Journal of Preventive Medicine. 2004;26(2):152-155. [pmid: 14751328].
143 Bowns IR, Collins K, Walters SJ, et al. Telemedicine in dermatology: a randomised controlled trial. Health Technology Assessment (Winchester, England). 2006;10(43):iii-iiv.
144 Ericson MB, Sandberg C, Gudmundson F, et al. Fluorescence contrast and threshold limit: implications for photodynamic diagnosis of basal cell carcinoma. Journal of Photochemistry & Photobiology. 2003;B(2):121-127.