# Next Steps

Only three trials examined the use of dermoscopy versus naked eye examination in the evaluation of suspicious skin lesions. Only one reported diagnostic accuracy of dermoscopy compared with naked eye examination.55 The focus of the other two studies did not concern diagnostic accuracy (one examined the time needed to complete exam with and without dermoscopy;59 the other studied the referral rate for biopsy with and without dermoscopy56) A trial based on a larger number of dermatologists and primary care physicians in the U.S. and using biopsy result as the reference standard and reporting on both intermediate (e.g., number of lesions) and clinical outcomes (e.g., survival) would be informative.

Key informant input suggests that the main challenge to the use of dermoscopy in a primary care setting lies in the training (or lack of) of nonexperts in its technique. As most of the studies on training focused on dermatologists, it would be important to investigate the kinds of training appropriate for primary care practitioners before this technique could be incorporated in a primary care setting.

Because of the wide range of reported diagnostic sensitivities and specificities for the standard dermoscopic algorithms in use, studies should be conducted to better understand the determinants of this reported variability.

A limited number of studies reported on the use of computer-aided diagnoses of suspicious skin lesion. It would be informative to further evaluate the performance of automated computer diagnostic instruments vis-à-vis the ability of an experienced clinician to diagnose skin cancer. It is also important to analyze further specific attributes of images captured by these noninvasive devices (including dermoscopy, confocal laser scanning microscopy, etc.) for their use in computer-aided diagnosis (such as a neural network classifier).

In contrast to the widespread use of many of photodynamic therapies for NMSC and benign skin disorders, the clinical use of photodynamic diagnostic techniques is still investigational. At present, its principal role may be in defining the borders of suspicious lesions, particularly for NMSC, and in differentiating tumor tissue from normal tissue. Whether the use of alternative light sources, like laser, with photodynamic compounds, is helpful in diagnosing melanoma deserves further exploration.

Even though intermediate/process outcomes are important in the use of these noninvasive technologies (e.g., decreasing the interval between referral to specialist and diagnosis and initiation of treatment) to further appreciate their impact, long-term follow up studies with patient-centered outcomes, such as survival and reduction of unnecessary biopsies, should also be undertaken.

To improve understanding of the diffusion of these different technologies, it would be useful to explore how specific population/patient/practice settings (e.g., rural versus urban, individuals with or without previous history of cancer or of different ethnic/racial backgrounds, availability of trained specialists) affect the use and adoption of these newer technologies.