# Methods

## Systematic Searches of the Published Literature

We conducted an electronic literature search in MEDLINE^®^ for articles published between 1990 and March 2011.Our search strategy utilized both National Library of Medicine Medical Subject Headings (MeSH^®^) and search terms. The identification of search terms for noninvasive modalities was guided by information from the earlier Topic Refinement phase of this project. To develop search terms for skin cancer, we used a previously published skin cancer systematic review as a reference.18 Search terms for noninvasive modalities were crossed with search terms for skin cancer. We restricted our search to literature published within the last 20 years because all noninvasive modalities of interest are fairly new. We also restricted our search to English-language human subject studies. Because the specific focus of the search was not screening and detection for specific types of skin cancer, (e.g., melanoma or nonmelanoma), we did not seek to identify or formally evaluate existing guidelines. Selected examples from the National Guideline Clearinghouse (www.guideline.gov) are included for background information only. The details of our search strategies are listed in Appendix A. In particular, we noted that while ‘dermoscopy’ has been used in MEDLINE^®^ since 2005 as an inclusive term for dermatoscopy, epiluminescence microscopy, or surface microscopy, studies prior to 2005 needed to be identified by the alternative terminologies. The first 200 abstracts were screened jointly by all project investigators to ensure that screening criteria were well understood and applied uniformly. Thereafter, investigators screened non-overlapping sets of the remaining citations. In general, abstracts served as the primary source of information, which were supplemented by full-text review of systematic reviews (n=5) and all randomized controlled trials (RCTs) (n=11). We did not do a pre-MEDLINE^®^ search.

Because our report primarily focused on the use of noninvasive modalities for the early diagnosis of skin cancer, we excluded studies of metastases detection, therapeutic interventions, or modalities used exclusively for pre-surgical planning. Specifically, we did not consider ^18^F-FDG positron emission tomography (PET), computed tomography (CT), single photon emission computed tomography (SPECT), and lymphoscintigraphy in this technology brief because these techniques are not generally used in initial screening of suspicious skin lesions or establishing the diagnosis of skin cancer, but rather, in delineating loco-regional or distance spread of disease. In addition, given our focus on the evaluation of primary cutaneous lesions, we also excluded evaluation of subungal, ocular, and visceral sites of disease. Appendix B, Table 1 summarizes our inclusion and exclusion criteria.

## Searches of the Grey Literature

We performed an Internet search for key words to identify more recent noninvasive techniques/modalities not in current widespread use, such as fluorescence, high-resolution ultrasound, laser Doppler, bio-electrical impedance, polarized light photography, 3-D histograms of color mapping, and thermography. For these searches, unless otherwise advised, we used the Google search engine, and, for each search string entered, we perused the first 10 pages to identify relevant links.

In addition to our Internet search, we reviewed major vendors or manufacturers' Web sites for information pertaining to the different noninvasive modalities. To identify major vendors or manufacturers and to obtain FDA clearance status of relevant devices (see Appendix C, Table C1), we searched the FDA Center for Devices and Radiological Health (CDRH) database. We compiled a list of noninvasive devices using information from published reviews as well as information gleaned from our Technical Experts. For potential harms with the relevant devices, we queried the FDA Manufacturer and User Facility Device Experience (MAUDE) database for any reported harms with the use of the relevant devices.

Also, we searched the ClinicalTrials.gov registry for any ongoing or completed relevant trials involving the various noninvasive modalities of interest. We used both device categories and name of device (such as MoleMax and Vivascope^®^) and device category when searching the registry (see Appendix C, Table C2).

## Interviews With Key Informants

A representative panel of Key Informants was identified through the earlier Topic Refinement phase of this project. These individuals included medical experts/practitioners in dermatology, oncology, and family medicine, a patient with skin cancer and a representative of patient advocacy group, as well as scientists and representatives of professional societies.

Technical experts within the Key Informant group were individually interviewed by phone or email for their responses to Guiding Questions 1, 2, and 4. Interview questions were tailored to the unique perspective and expertise of each Technical Expert. The final structure of the brief in reference to classification of technologies by degree of clinical use was also reviewed. All external participants completed disclosure of interest forms and any conflicts were considered and balanced.

## Data Collection

Data from abstracts of qualified studies were extracted into an Excel spreadsheet. We extracted information on items of interest (population, intervention, comparator, outcome [PICO]), using customized forms, including information specific to the particular noninvasive modality. We also extracted data on the citation (first author name, journal, and year of publication), condition being evaluated, study size and setting, particular noninvasive modality, and details relevant to the technical specification of the particular noninvasive modality. We categorized, wherever possible, qualified studies into the two major categories: reviews, which included systematic review, general or narrative review, and technical report; or primary studies, which included RCTs, comparative cohort, non-comparative cohort or case series, diagnostic tests, or single case reports. Studies that did not fit into one of these two groups were considered “other.” An abstract was classified as a systematic review if it described the study as a meta-analysis, pooled analysis, or systematic review. An abstract was also classified as a systematic review if it reported that there were inclusion or exclusion criteria in selecting the studies. We documented the outcomes as test accuracy (e.g., sensitivity, specificity, false positive rate, false negative rate), clinical outcomes (e.g., survival), characterization of the skin lesion (e.g., lesion size, lesion color), and other. The “other” category pertained to intermediate outcomes (e.g., number of lesion) or process outcomes (e.g., patient satisfaction, healthcare utilization), training for optimizing the use of device, or description of use.

## Data Organization and Presentation

To address the guiding questions, we combined our systematic review of abstracts of current published literature with key informant interviews and a perusal of grey literature. Devices were classified as those in general clinical use, limited clinical use, or investigational use, based on all available information; the results are organized to reflect this. For devices in general or limited clinical use, we have presented information based on available literature on: description of technique; theoretical advantages and disadvantages; variations of technique; clinical context of use, FDA status, as well as ethical, privacy, equity, and cost considerations when this information is available. For investigational devices, given the scarcity of published literature, we have provided a summary paragraph, including a description of the device and its potential future applications. For each diagnostic modality, technical descriptions were synthesized using information extracted from the most recent and most comprehensive narrative review(s) available.