# Guiding Questions

Our analysis of the current literature was based on the following guiding questions. These guiding questions are partly derived from the hierarchical model of technology assessment first proposed by Thornbury and Fryback in 1992.^17^ According to this hierarchical model, there are six sequential levels to be considered in the evaluation of a technology assessment. They are: (1) technical efficacy, (2) diagnostic accuracy efficacy, (3) diagnostic thinking efficacy, (4) therapeutic efficacy, (5) patient outcome efficacy, and (6) societal efficacy. Each level is built upon the previous level. The guiding questions posed to the different technologies will be addressed to the extent that they have satisfied the sequential levels (e.g., some of the modalities have not progressed beyond the first level of technical efficacy stage and therefore it makes little sense to assess the second level questions like diagnostic accuracy).

Guiding Question 1 What are the different noninvasive techniques/modalities that have been proposed to be used for the early detection of skin cancer?
  i. What are the postulated advantages and disadvantages of these noninvasive diagnostic techniques compared with biopsy, among individuals who should be considered for these technologies?
  ii. What are the potential safety issues and harms associated with the use of noninvasive diagnostic techniques for the evaluation of suspicious skin lesions?
  iii. What is the current FDA clearance status of these modalities?
  iv. What kinds of training and certifications are needed to use these techniques/modalities?
  v. What are some of the newer techniques/modalities in development?
Guiding Question 2 What is the current clinical context in which these new noninvasive modalities are used—who uses them, in what setting, for which cancers, with which patients?
  i. Are there reasons to consider that some techniques may be more or less effective for the early detection of skin cancers in those patients who had a previous history of skin cancer, previous history of any cancer, or no history of cancer?
  ii. Are there reasons to consider that some techniques may be more or less effective for the early detection of skin cancers among Whites, Blacks, and Hispanics?
Guiding Question 3 What published and unpublished studies have reported on the use and safety of these noninvasive modalities? Provide a synthesis of the following information
  i. Indication/patient inclusion criteria
  ii. Study design and size
  iii. Role of the test in patient management
  iv. Outcomes assessed
  v. Adverse events, harms, and safety issues reported
  vi. Comparators used (applicable only to comparative studies)
  vii. Length of follow-up (applicable only to longitudinal studies)
Guiding Question 4 What is the projected diffusion of these different techniques/modalities in the near future? What are potential areas for future research that are most meaningful given the current state of the evidence and the projected diffusion of these techniques/modalities?

## Analytic Framework

The analytic framework addresses the evaluation of patients with suspicious skin lesions, who, based on their own characteristics (such as prior history or other risk factors) or the setting in which they seek care (primary, specialty, or subspecialty care), may be considered as candidates for assessment with noninvasive techniques. Eligible patients would be considered for one or more of the noninvasive techniques prior to or in lieu of biopsy. The specific device(s) selected could be those in general clinical use (i.e., photography and dermoscopy), limited clinical use or investigational, based on availability and suitability of the device to address the clinical problem. The framework is designed to include a feedback loop that leads to biopsy if either the evaluation were positive or referred back for further followup. The importance of clinical setting (availability of the device and suitable levels of training/competency) and the patient's individual characteristics are considered at multiple junctures within the framework. Solid wiggly lines generally indicate associations/relationships that are present, but not direct or not of our interest. They can be impact of effect modifiers, or adverse effects of interventions. The dotted wiggly line between the noninvasive test box and the biopsy box indicates that we were comparing between the two tests.

Figure 1 Analytic framework

Figure 1 represents the analytic framework for the technical review, which addressed the evaluation of patients with suspicious skin lesions. The figure shows that candidates for assessment with non-invasive techniques (prior to or in lieu of biopsy) are those with prior history or other risk factors who seek care in a primary, specialty, or subspecialty setting. The specific device(s) selected could be those in general clinical use (i.e., photography and dermoscopy), or in limited clinical use or investigational, based on availability and suitability of the device to address the clinical problem. The framework is designed to include a feedback loop in which the patient would either proceed to biopsy if the evaluation were positive or referred back for further followup. The importance of clinical setting (availability of the device and suitable levels of training/competency) and the patient's individual characteristics are considered at multiple junctures within the framework.