# Background

Cancers of the skin are the most common forms of cancer in men and women, and account for nearly half of all malignancies. In 2009, more than 1 million cases were expected in the United States.1 Basal cell carcinoma (BCC) and squamous cell carcinoma (SCC), two types of nonmelanomatous lesions associated with aging and sun exposure, are responsible for more than 800,000 cases per year.1 Recent studies have also linked nonmelanoma skin cancer (NMSC) to prior cancer therapy, especially radiation therapy.2 While NMSC is rarely lethal, these lesions are associated with other malignancies (including hematologic and respiratory tract cancers).3 In contrast, melanoma accounts for approximately 4 percent of all skin cancer cases, but causes the majority of skin cancer deaths.4 One study found that melanoma incidence rates had doubled in all socioeconomic groups over a 10-year period.5 Another study found that melanoma incidence rates have increased by 3 percent per year in white Hispanic and white non-Hispanic populations, and both white Hispanic and Black populations had more advanced disease at presentation.6 Melanoma is associated with significant morbidity, and late stage melanoma with significant mortality due to the likelihood of metastatic spread.7,8

Therefore, timely diagnosis and treatment are critical to reducing rates of morbidity and mortality of all skin cancers. However, suboptimal diagnostic accuracy of current methods of lesion assessment (such as visual inspection) may lead to misleading false positives or conversely missed diagnoses, and the existing protocol of excisional biopsy of suspected lesions is an invasive, costly, and time-intensive procedure. Newer noninvasive screening and diagnostic modalities are available that may provide more precise imaging of suspected lesions and more accurate detection, thereby improving in vivo diagnosis. These newer technologies may, therefore, assist with earlier detection, eliminate unnecessary biopsies, and reduce costs and patient time spent in the physician's office.

## Current and Emerging Modalities of Assessment and Diagnosis

Several groups in Europe, North America, Australia, and New Zealand have developed guidelines for the screening and prevention of skin cancer.9-12 According to a 2009 Guideline Synthesis, while there is general agreement that there is insufficient evidence to support screening of the general population for skin cancer, increased surveillance for individuals at higher risk is generally recommended.13

According to Goodson 2009, most dermatologists would agree that the goals of monitoring of nevi and detection of melanoma include the identification of high-risk patients, early biopsy of suspected melanomas, monitoring of nevi, and the avoidance of unnecessary biopsies.14 High-risk patients in the case of melanoma include those patients with a personal history of melanoma, family history, suspicious skin lesions (e.g., atypical nevi), and other risk factors (e.g., age ≥50 years, prior history of cancer). For patients with suspected SCC or BCC, a goal of management is to reduce potentially disfiguring biopsies.

The assessment of suspicious skin lesions typically begins with a physical examination and visual inspection of the skin with the naked eye. Full body and digital photography, which augments visual inspection, are used across different practice settings and specialty groups. In addition, many dermatologists use dermoscopy (also known as dermatoscopy, epiluminescence microscopy, or surface microscopy) to better examine the lesion. The dermoscope is a magnifying lens equipped with a polarized or nonpolarized light source (to deflect surface reflection) that is held near the suspicious lesion. Other diagnostic techniques include confocal microscopy, which produces images of skin lesions at various depths and is primarily used in research centers. Some of these devices have been approved or cleared by the FDA; others are in general use (e.g., photography). In addition, a number of imaging modalities are emerging to help improve the diagnostic accuracy of visual inspection of pigmented skin lesions. These include epidermal genetic tape stripping, ‘scent’/‘odor’ ultraviolet photography, fluorescence, ultrasound, laser Doppler, bio-electrical impedance, polarized light photography, 3-D histograms of color mapping, multispectral imaging and fully automated computer-based analysis, and thermography.15 To evaluate these newer techniques, several comparators have been used. In addition to the direct comparison with the “gold standard,” the biopsy, several studies have highlight comparisons between the newer devices and the clinical exam, as well as head-to-head comparisons between these devices.

## Statement of Work/Objectives

The objectives of this technical brief are to provide a description of the state of the science of noninvasive imaging modalities in diagnosing cancerous tumors of the skin, proffer an analytic framework for assessing the applications of the devices, provide a summary of ongoing research, and to delineate future research needs.

Three principal forms of skin cancer will be considered: basal cell carcinoma (BCC) and squamous cell carcinoma (SCC), the more prevalent forms of skin cancer, and melanoma, among the most virulent. While the focus of this brief will be on modalities currently in general or limited clinical use and/or FDA approved or cleared, we also will consider investigational technologies based on available data and input from our key informants particularly the potential importance of these technologies and where they might fit into the care process.

For the purpose of the present discussion, we considered these modalities according to the degree of resolution of the skin lesions, ranging from clinical inspection (quaternary and tertiary) to delineation of cellular and subcellular structures (secondary and primary), adapted from Marghoob 2003.^16^ We also examine whether there are indications of differing effectiveness among techniques for the early detection of skin cancers among Whites, Blacks, and Hispanics, and whether that should be a focus of future comparative effectiveness research. Whenever possible, we stratify the findings by whether or not the patients had a previous history of skin cancer and whether or not patients have a history of other malignancies. The rationale for this is the growing recognition of skin cancer as a leading form of second malignancy.1,11 We also sought to assess the clinical application of these modalities and their diffusion across specialty/subspecialty groups.