# Appendixes

Appendix A Search Strategies

Appendix B Inclusion and Exclusion Criteria

Appendix C FDA Clearance and Clinical Trials Status

Appendix D Evidence Maps and Outcome Measures

Appendix E Abbreviations