# Abbreviations

ABCD: Asymmetry, border, color, and differential structure
ALA: Aminolevulinic acid
BCC: Basal cell carcinoma
CDRH: Center for Devices and Radiological Health
CSLM: Confocal scanning laser microscopy
CT: Computed tomography
EGIR: Epidermal Genetic Information Retrieval
FDA: Food and Drug Administration
GP: General practitioner
MAUDE: Manufacturer and User Facility Device Experience
MeSH: Medical Subject Headings
MRI: Magnetic resonance imaging
NCT: National Clinical Trial
NMSC: Non-melanoma skin cancer
OCT: Optical Coherence Tomography
PDD: Photodynamic diagnosis
PET: Positron emission tomography
PICO: Population, intervention, comparison, and outcome
PpIX: Protoporphyrin IX
SCC: Squamous cell carcinoma
SPECT: Single photon emission computed tomography
TBP: Total body photography