# Evidence Maps and Outcome Measures

Table D-1 Evidence map of published abstracts for noninvasive diagnostic devices by clinical use status (N=583^a^)

| Reviews (N=232) | | | Primary Studies (N=351)
Noninvasive technologies | Narrative reviews | Technical reports | Systematic reviews | RCT | Comparative cohorts | Non-comparative cohorts | Diagnostic tests | Single case reports
Modalities in general clinical use
Photography | 4 | 4 | -- | 7^b^ | 11 | 13 | 5 | -
Dermoscopy | 78 | 71 | 5 | 3 | 39 | 96 | 52 | 49
Subtotal | 81 | 74 | 5 | 10 | 50 | 109 | 57 | 49
Modalities in limited clinical use
Confocal microscopy | 17 | 12 | -- | -- | 6 | 26 | 7 | 4
Ultrasound/Laser Doppler | 6 | 12 | -- | -- | 2 | 7 | 7 | --
Photodynamic diagnosis | 9 | 7 | -- | 1 | 4 | -- | -- | 1
Subtotal | 32 | 31 | 0 | 1 | 12 | 33 | 14 | 5
Investigational
Multiphoton laser scanning microscopy | 3 | -- | -- | -- | -- | -- | 2 | --
Multispectral imaging and fully automated computer-based analysis | 1^c^ | -- | -- | -- | -- | -- | 1 | --
Electrical bio-impedance | -- | -- | -- | -- | 1 | 2 | 2 | --
Optical coherence tomography | 1 | 2 | -- | -- | 1 | 1 | -- | --
Tape stripping | -- | -- | -- | -- | -- | -- | 1 | --
Thermography | 1 | -- | -- | -- | -- | -- | -- | --
Subtotal | 6 | 2 | 0 | 0 | 2 | 3 | 6 | 0
Total | 119 | 108 | 5 | 11 | 64 | 144 | 77 | 55

a Subset of 629 abstracts designated as either a review article or primary study focusing on a single diagnostic modality, some review articles have been counted in more than one category, therefore, the individual numbers may not sum up to the subtotal.

b 6 unique RCTs produced 7 individual abstracts.

c Review also covered other topics (e.g., dermoscopy).

Table D-2 Evidence map of published abstracts for noninvasive diagnostic devices by skin cancer type

Noninvasive technologies | Melanoma | Basal cell carcinoma | Squamous cell carcinoma | Other^a^
Modalities in clinical use
Photography | 28 | 1 | - | 22
Dermoscopy | 236 | 22 | 5 | 58
Modalities in limited clinical use
Confocal microscopy | 29 | 13 | 2 | 28
Ultrasound | 9 | 3 | - | 19
Photodynamic diagnosis | 2 | 16 | - | 4
Investigational
Multiphoton laser scanning microscopy | - | - | - | 5
Multispectral imaging and fully automated computer-based analysis | 1 | - | - | -
Electrical bio-impedance | - | 3 | - | 2
Optical coherence tomography | 1 | 1 | - | 3
Tape stripping | 1 | - | - | -
Thermography | 1 | - | - | -
Total | 308 | 59 | 7 | 141

a Includes “malignancies of the skin, not otherwise specified” and “skin cancer combinations.”

Table D-3 RCTs identified in the present technical brief

First Author UI Country year | Study Objective | Comparisons | Setting | Population (N) Mean age, yrs Males (%) Race Cancer type | Type of Outcome, Followup duration | Outcome, Adverse events
Photography
Del Mar CB138 7888887 Australia 1995 | To evaluate excision rate of benign melanocytic nevi | General practitioners (GPs) with a camera vs. GPs with no camera | Primary care | 108 GPs (5784 pts with suspicious nevus) 28.2 years (pt level) 43.4% male (pt level) No data on race (study conducted in Australia) Melanoma | Intermediate outcomes Followup = 2 years | Outcomes: Excision rates of benign melanocytic nevi No adverse events reported
Hanrahan PF139, 140 11215011 12370325 Australia 2000;2002 | To assess the utility of photographs for skin cancer management | Patient received photographs vs. patients with no photographs | Primary care | 973 male > 50 years agreed to participate 62.0 years 100.0% male No data on race (study conducted in New South Wales) Melanoma | Test accuracy Intermediate outcomes Followup = 2 years | Outcomes: Diagnostic accuracy between those using and not using photography Effect of photography on management of lesion (leave lesion for followup, cryotherapy) Cost savings of photography No adverse events reported
English DR141 12919990 Australia 2003 | To evaluate the ratio of benign to malignant excision | GPs with a camera and algorithm vs. GPs with no camera | Primary care setting | 468 GPs(223 practices) No data on age No data on race Melanoma | Intermediate outcomes Followup duration unclear | Outcome: Ratio of benign to malignant melanoma excised. No adverse events reported
Oliveria SA142 14751328 USA 2004 | To assess the impact of nurse-delivered intervention with digital photographs to increase patient adherence to skin self examination | Teaching intervention with photo-book vs. teaching intervention alone | Primary care setting | 100 high-risk patients Control age:38 years Control male%:33.3 Dysplastic/atypical nevi | Intermediate outcomes Followup = 4 months | Outcomes: Adherence to skin self examination. No adverse events reported.
Chiu V28 16844506 USA 2006 | To examine the accuracy of skin self examination | Mole mapping vs. no mole mapping. | Primary care setting | 88 patients Control age:>50 yrs, 57% males in mole mapping group Control males: 52% Suspicious skin lesions | Intermediate outcomes Followup = 2 weeks | Outcome: Percentage of patients that gave accurate assessment of lesions
Bowns IR143 17049140 2006 UK | To compare tele-dermatology with face to face consultation | Tele-consultation vs. face to face consultation evaluating diagnostic concordance between physicians | Specialist setting (dermatology) | 208 patients 46.3 years 37.4% male No data on race Any malignancy | Test accuracy Process outcomes Followup duration: NA | Outcomes: Diagnostic concordance between physicians—Sn, Sp Number of followup visits Patients' satisfaction with care Adverse events: not reported
Dermoscopy
Carli P56 15097950 Italy 2004 | To assess the impact of dermoscopy on lesion management | Naked eye and dermoscopy vs. naked eye alone | Pigmented lesion clinic (dermatology) | 913 patients 36 years 43% male No data on race Melanoma | Intermediate outcomes Followup = 6 months | Outcomes: Percentage of patients referred for surgery Number of melanoma excised Adverse events: not reported
Argenziano G55 16622262 Barcelona, Spain, Naples, Italy 2006 | To evaluate the effect of dermoscopy on the diagnostic accuracy of primary care practitioners | Dermoscopy evaluation vs. naked eye evaluation | Primary care setting | 73 PCPs 2522 patients 40.5 years 38% male No data on race Any malignancy | Test accuracy Followup = 16 months | Outcomes: Sn, Sp, NPV, PPV Adverse events: not reported
Zalaudek I59 18427045 2008 Austria | To determine the time required to complete skin examination with or without dermoscopy | Skin exam and dermoscopy vs. skin exam alone | Pigmented lesion clinic (dermatology) | 1359 patients 39.5 years 45.9% male No data on race Any malignancy | Process outcomes Followup duration: NA | Outcome: Median time required for complete skin examination Adverse events: not reported
Photodynamic diagnosis
Ericson MB144 12633984 2003 Sweden | To evaluate tolerance threshold of photo-diagnosis by evaluating ratio of fluorescence intensity between ALA treated tumor tissue and normal skin | 4 groups with varying ALA application time, from 1 to 4 hrs | dermatologist | 40 patients Age: nd No data on % male No data on race Basal cell carcinoma | Other outcomes Followup duration: NA | Outcomes: Ratio of fluorescence intensity between ALA treated tumor tissue and normal skin Fluorescence intensity variation in ALA-treated normal skin Adverse events: not reported

ALA = 5-aminolevulinic acid, GPs = general practitioners, nd = no data, NPV = negative predictive value, PCPs = primary care physicians, PPV = positive predictive value; Sn = sensitivity; Sp =specificity.

Table D-4 Outcome measures reported in the published primary studies for noninvasive diagnostic devicesˆ

Noninvasive technologies | Test accuracy | Clinical outcomes | Lesion characterization | Other
Modalities in clinical use
Photography | 9 | 0 | 10 | 18
Dermoscopy | 92 | 1 | 83 | 63
Modalities in limited clinical use
Confocal microscopy | 15 | 0 | 24 | 3
Ultrasound / Laser Doppler | 5 | 0 | 8 | 3
Photodynamic diagnosis | 3 | 0 | 2 | 1
Investigational
Multiphoton laser scanning microscopy | 2 | 0 | 0 | 0
Multispectral imaging and fully automated computer-based analysis | 1 | 0 | 0 | 0
Electrical bio-impedance | 2 | 0 | 0 | 3
Optical coherence tomography | 1 | 0 | 2 | 0
Tape stripping | 2 | 0 | 0 | 0

ˆ Thermography is not included in this table as no primary studies on thermography were identified.