# FDA Clearance and Clinical Trials Status

Table C-1 Available U.S. FDA clearance status for noninvasive skin cancer diagnostic devices

Device name | Company (country) Web site | FDA clearance status | Intended use
DERMOSCOPY
EpiScope (MODEL 47300) | Welch Allyn (USA) www.welchallyn.com | - Approved by the FDA Class I device; - 510(K920103); - FDA decision date: 04/28/1992 | To illuminate body surfaces and cavities
Nevoscope | TransLite (USA) www.tlite.com | - Approved by the FDA as Class I device; - 510(K954943); - FDA decision date: 03/27/1996 | To view skin lesions by either surface illumination or transillumination
Dermascope | American Diagnostic Corp. (USA) www.adctoday.com | - Approved by the FDA as Class I device in 1999 | To enlarge images for medical purposes
MoleMax | Derma Medical Systems www.dermamedicalsyste ms.com | - Approved by the FDA as Class I device in 1999 | To enlarge images for medical purposes
MicroDerm | Visiomed AG (USA) www.visiomedag.com | - Approved by the FDA as Class II device; - 510(K032760); - FDA decision date: 04/27/2004 | To acquire and store images of skin surfaces
CONFOCAL MICROSCOPY
VivaScope® 1500 VivaScope® 2500 VivaScope® 3000 | Lucid, Inc. (USA) www.lucid-tech.com | - Approved by the FDA as Class II device; - 510(k) number: K080788; - FDA decision date: 09/05/2008 | To acquire, store, retrieve, display, and transfer in vivo images of tissue
Optiscan™ | Optiscan Pty Ltd (Australia) www.optiscan.com | - Approved by the FDA as Class II device; - 510(k) number: K093624; - FDA decision date: 02/19/2010 | This device was listed as a confocal microscopy device for skin lesion evaluation in a published review.37 However, the intended use listed in the FDA summary is for the imaging of the internal microstructure of tissues during endoscopic medical procedures.
ULTRASOUND/LASER DOPPLER
Cortex Dermascan C Ultrasonic System | Cortex Technology APS (Denmark) www.cortex.dk/ | - Approved by the FDA; - 510(K983945); - FDA decision date: 03/17/1999 | To visualize layers of the skin, including blood vessels
DUB 20 | G.W.B. INTL., LTD. (USA) | - Approved by the FDA as Class II device; - 510(K896029); - FDA decision date: 01/12/1990 | No data available
SSA-340 A (Modification) | Toshiba America Medical System, Inc. (USA) www.medical.toshiba.com | - Approved by the FDA as Class II device; - 510(K960602); - FDA decision date: 03/21/1996 | To accentuate minute vascular structures and signal presence of blood
Sonoline Elegra Diagnostic Ultrasound System | Siemens Medical Solutions USA, Inc.(USA) | - Approved by the FDA as a Class II device; - 510(K003125); - FDA decision date: 10/20/2000 | For peripheral vascular applications, not specified
MULTISPECTRAL IMAGING AND FULLY AUTOMATED COMPUTER-BASED ANALYSIS
MelaFind | Electro-Optical Sciences, Inc. (USA) www.eosciences.com | - Unproven procedure; - Filed a pre-market approval application in June 2009; - FDA advisory panel meeting (Nov. 18, 2010): voted 8-7, a recommendation for approval of MelaFind as a skin cancer detection device

Table C-2 Studies of noninvasive diagnostic techniques for the detection of skin cancer on the clinicaltrials.gov registry

NCT number | Study design | Type of technology | Study status | Last updated | Results
PHOTOGRAPHY
No registered study was identified for this modality.
DERMOSCOPY
00765193 | Cohort | Dermoscopy (as needed) | Completed | April 4, 2010 | Posted
CONFOCAL MICROSCOPY
00601185 | Non-randomized diagnostic study | Reflectance confocal microscopy | Completed | January 27, 2010 | Not posted
00785369 | Non-randomized diagnostic study | Reflectance confocal microscopy | Completed | Feb 3, 2010 | Not posted
00487864 | Observational non-comparative cohort | Confocal scanning laser microscopy | Completed | June 18, 2007 | Not posted
01010321 | Observational case-series | Confocal microscopy | Suspended | June 27, 2010 | NA
00771355 | Observational case-series | Reflectance confocal microscopy | Recruiting participants; estimated completion date is July 2010 | May 3, 2010 | NA
00588315 | Case-control | Confocal microscopy | Recruiting participants; estimated completion date is December 2010 | June 22, 2010 | NA
00574392 | Observational non-comparative cohort | Reflectance confocal microscopy | Ongoing but not recruiting participants; estimated completion date is November 2011 | October 8, 2010 | NA
01194947 | Case-series | Reflectance confocal microscopy | Not yet open for recruitment; estimated completion date is September 2013 | September 22, 2010 | NA
00663910 | Non-randomized pilot study | Reflectance confocal microscopy^*^ | Not yet open for recruitment; estimated completion date is March 2010 | December 1, 2009 | NA
ULTRASOUND WITH LASER DOPPLER
00776945 | Observational | Ultrasound with laser Doppler | Ongoing. Estimated primary completion date is December 2014 | November 12, 2009 | NA
PHOTODYNAMIC DIAGNOSIS
No registered study was identified for this modality (except as noted above^*^)
MULTIPHOTON LASER SCANNING MICROSCOPY
00154921 | Cross-sectional | Two-photon fluorescence microscopy | Recruiting participants; estimated study completion date is December 2007 | November 22, 2005 | NA
00508781 | Cross-sectional | Multiphoton laser scanning microscopy | Recruiting participants; estimated study completion date is December 2012 | July 26, 2007 | NA
ELECTRICAL BIO-IMPEDENCE
00966173 | Observational non-comparative cohort | Electrical impedance spectrometer | Completed | August 10, 2010 | Not posted
01077050 | Observational non-comparative cohort | Electrical impedance spectrometer | Recruiting participants; estimated study completion date is April 2010 | May 19, 2010 | NA
MULTISPECTRAL IMAGING AND FULLY AUTOMATED COMPUTER-BASED ANALYSIS
00434057 | Non-randomized diagnostic study | MelaFind | Completed | November 10, 2009 | Posted
01011153 | Observational Cross-sectional | MelaFind | Estimated primary completion date is December 2009 | November 10, 2009 | Not posted
OPTICAL COHERENCE TOMOGRAPHY
00390351 | Cross-sectional | Optical coherence tomography | Recruiting participants; estimated completion date is July 2008 | October 18, 2006 | NA
TAPE STRIPPING
00482105 | Observational non-comparative cohort | EGIR™ tape stripping | Terminated | May 7, 2009 | Not posted
THERMOGRAPHY
No registered study was identified for this modality

Source: http://www.clinicaltrials.gov

* This study evaluates the effect of topical application of 5-aminolevulinic acid photodynamic therapy on protoporphyrin formation among non-melanoma skin cancer patients. The primary purpose of this study was not to evaluate confocal microscopy per se, but confocal microscopy was used as part of the study outcome assessment.