# Inclusion and Exclusion Criteria

Table B-1 Literature abstract screening (PICO) criteria

| Inclusion criteria | Exclusion criteria
Population (P) | - History of past or current skin cancer: melanoma, basal cell carcinoma, squamous cell carcinoma; - Patients with new or recurrent pigmented or suspicious skin lesions, including facial skin cancers, basal cell nevus syndrome, and Gorlin's Syndrome; - Included all age, race, sex, and countries | - All other skin cancers; - Kaposi's sarcoma; - Merkel cell carcinoma; - Mycosis fungoides; - Skin lymphoma; - Sézary syndrome; - Choroidal melanoma; - Subungal, ocular, and visceral lesions; - Head and neck cancers; - Metastases
Diagnostic device of interest (I) | - General; - Full body photography; - Digital photography; - Dermoscopy; - Limited Use; - Confocal microscopy; - Ultrasound, including laser Doppler, color mapping; - Photodynamic diagnosis; - Investigational; - Multiphoton laser scanning microscopy; - Multispectral imaging with computer-analysis; - Optical coherence tomography; - Epidermal genetic tape stripping; - Bio-electrical impedance; - Thermography | - Spectrophotometric intracutaneous Analysis (SIAscopy); - Spectrophotometry; - Photoacoustic microscopy; - Photodynamic therapy (PDT); - Colorimetry; - ^18^F-FDG positron emission tomography (PET); - Computer tomography (CT); - Single photon emission computed tomography (SPECT); - Lymphoscintigraphy; - Fluorescent in situ hybridization; - Therapeutic interventions; - Pre-surgical planning
Comparator (C) | - Biopsy; - Any intervention and device listed above; - Clinical exam/assessment
Outcomes (O) | - Any clinical outcomes reported (including skin cancer survival and overall survival); - Quality of life measures; - Intermediate outcomes, e.g., changes in size and number of lesions; - Lesion characterizations; - Adverse events, harms, or safety data; - FDA clearance/approval status (if applicable); - Process measures, e.g., time to specialty referral, hospital wait times, healthcare utilization; - Diagnostic test accuracy, e.g., sensitivity, specificity, positive predictive value, negative predictive value | - Metastases detection; - Prognosis prediction
Study design | - Systematic reviews; - Narrative reviews; - Trials; - Comparative cohorts; - Case series; - Case reports; - Diagnostic tests