# Search Strategies

# | Search Terms
1 | exp Skin Neoplasms/
2 | exp “Neoplasms, Adnexal and Skin Appendage”/
3 | exp Melanoma/
4 | exp Carcinoma, Squamous Cell/
5 | exp Carcinoma, Basal Cell/
6 | exp Carcinoma, Merkel Cell/
7 | exp Lymphoma, T-Cell, Cutaneous/
8 | sarcoma, Kaposi/
9 | exp Nevus, Pigmented/
10 | (Basal adj2 carcinoma$).tw.
11 | (basal adj1 cancer$).tw.
12 | (basal adj1 neoplas$).tw.
13 | (basal adj1 tumo?r$).tw.
14 | (basal adj1 epithelioma$).tw.
15 | (basal adj1 malignan$).tw.
16 | basalioma$.tw.
17 | (basocellular$ adj carcinoma$).tw.
18 | BCC.tw.
19 | (basosquamous adj1 carcinoma$).tw.
20 | (squamous adj2 carcinoma$).tw.
21 | (squamous adj1 tumo?r$).tw.
22 | (squamous adj1 cancer$).tw.
23 | (squamous adj1 neoplas$).tw.
24 | (squamous adj1 epithelioma$).tw.
25 | (squamous adj1 malignan$).tw.
26 | SCC.tw.
27 | (merkel adj2 carcinoma$).tw.
28 | (merkel adj1 cancer$).tw.
29 | (merkel adj1 tumo?r$).tw.
30 | (merkel adj1 neoplas$).tw.
31 | (merkel adj1 malignan$).tw.
32 | MCC.tw.
33 | (t adj1 lymphoma$).tw.
34 | (cutaneous adj1 lymphoma$).tw.
35 | (mycos$ adj fungoid$).tw.
36 | sezary$.tw.
37 | (kaposi$ adj sarcoma$).tw.
38 | melanoma$.tw.
39 | (maligna$ adj2 lentigo).tw.
40 | LMM$1.tw.
41 | nonmelanoma$.tw.
42 | NMSC.tw.
43 | dermatofibrosarcoma$.tw.
44 | (apocrine adj carcinoma$).tw.
45 | (sweat adj1 carcinoma$).tw.
46 | (sweat adj1 tumo?r$).tw.
47 | (sweat adj1 neoplas$).tw.
48 | (sweat adj1 cancer$).tw.
49 | (sebaceous adj carcinoma$).tw.
50 | (sebaceous adj tumo?r$).tw.
51 | (sebaceous adj neoplas$).tw.
52 | (sebaceous adj cancer$).tw.
53 | (eccrine adj (poroma$ or porocarcinoma$)).tw.
54 | (eccrine adj epithelioma$).tw.
55 | SSDC.tw.
56 | Basal Cell Nevus Syndrome/
57 | ((naevoid or nevoid) adj3 syndrome$).tw.
58 | gorlin$.tw.
59 | (malignant adj1 (nev$ or naev$)).tw.
60 | ((skin or derm$ or cutaneous or epithelial or epidermoid$) adj1
61 | (cancer$ or neoplas$ orcarcinoma$ or tumo?r$ or malignan$)).tw.
62 | or/1-60
63 | (dermoscopy or dermoscope$1).mp. or exp Dermoscopy/
64 | full body photography.mp.
65 | exp Photography/ or digital photography.mp.
66 | *photography/
67 | 62 or 63 or 64 or 65 or 66
68 | tape stripping.mp.
69 | exp Fluorescence/ or fluorescence.mp.
70 | exp Ultrasonography/ or ultrasonography.mp.
71 | exp Laser-Doppler Flowmetry/ or laser Doppler.mp.
72 | exp Electric Impedance/ or electrical bio-impedance.mp.
73 | color mapping.mp.
74 | thermography.mp. or exp Thermography/
75 | skin surface microscopy.mp.
76 | skin surface microscopies.mp.
77 | dermatoscopy.mp.
78 | dermatoscopies.mp.
79 | microscopy, epiluminescence.mp.
80 | microscopies, skin surface.mp.
81 | epiluminescence microscopy.mp.
82 | microscopy, skin surface.mp.
83 | epiluminescence microscopies.mp.
84 | surface microscopy, skin.mp.
85 | microscopies, epiluminescence.mp.
86 | surface microscopies, skin.mp.
87 | color doppler.mp.
88 | incident light microscopy.mp.
89 | photodynamic diagnosis.mp.
90 | fluorescence diagnosis.mp.
91 | photodynamic detection.mp.
92 | fluorescence-based photodynamic diagnostic product.mp.
93 | fluorescent diagnostics.mp.
94 | photodiagnosis.mp.
95 | 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 94
96 | 67 or 95
97 | 61 and 96
98 | limit 97 to (English language and humans and yr=“1990 - Current”)