# Acknowledgments

The team gratefully acknowledges the assistance of James Gaylor and Lina Kong Win Chang in completing this technical brief, and the participation of our key informants in framing the research.