# Peer Reviewers

Frank Abrams

North Carolina State University

Raleigh, North Carolina

Debra Bemben

University of Oklahoma

Norman, Oklahoma

Everett Lohman

Loma Linda University

Loma Linda, California

Marco Pang

Hong Kong Polytechnic University

Hong Kong, Republic of China