# Key Informants

J. Christopher Fritton, Ph.D.

UMDNJ—New Jersey Medical School

Newark, New Jersey

Douglas P. Kiel, M.D., M.P.H.

Research & Training Institute, Hebrew

Rehabilitation Center for Aged

Harvard Medical School Division on Aging

Boston, Massachusetts

Pearl Liang

Health Mark, Inc.

Acworth, Georgia

Dawn Lowe, Ph.D.

University of Minnesota

Minneapolis, Minnesota

Kenneth J. McLeod, Ph.D.

Binghamton University, State University of New York

Binghamton, New York

Paul Osterbauer, D.C.

Northwestern Health Sciences University

Bloomington, Minnesota

Margaret Pittenger, P.T.

Health Mark, Inc.

Acworth, Georgia

Susan Randall

National Osteoporosis Foundation

Washington, District of Columbia

Clinton T. Rubin, Ph.D.

State University of New York

Stony Brook, New York

Don Wickstrom

VibraTrim, L.L.C.

Gig Harbor, Washington

Kevin Wince

Health Mark, Incorporated

Acworth, Georgia