# Summary and Implications

## Important Issues Raised by the Technology

Little scientific evidence evaluates the benefits and harms of whole-body vibration therapy for the prevention and treatment of osteoporosis. Key informants unanimously urged caution in making claims about whole-body vibration for osteoporosis because of the lack of evidence about the optimal target population, optimal treatment protocol, and long-term effects. Other issues of concern emerged in the published literature and in key informant discussions.

It is not clear which population groups might benefit from whole-body vibration, or whether certain groups may be more susceptible to harms. Published studies focused on individuals with osteoporosis, individuals with low BMD, and individuals at risk for osteoporosis or low BMD. Since only a few studies assess each of these groups, the literature lacks clear guidance about the optimal target population. Additionally, there is no clear evidence for individuals with different risks for osteoporosis or severity of the disease. Key informants differed in opinion about the optimal population group for whole-body vibration therapy. Most published studies excluded individuals with health issues, such as heart problems or musculoskeletal problems, so the potential harms for individuals with certain health conditions remain unclear. Key informants mentioned that the effects of whole-body vibration are unknown for some individuals, and they listed contraindications such as joint replacement. Treatment protocols varied widely among the published studies, reflecting uncertainty regarding the platform type, platform settings, and session length and frequency that may be necessary to demonstrate measureable benefits for the prevention and treatment of osteoporosis. Studies also varied in other aspects of the treatment protocol, such as whether participants flexed their knees while on the platform, performed dynamic exercises while on the platform, or were required to wear specific footwear while standing on the platform and whether platform settings changed during vibration sessions or intervention period, so the impact of these aspects on treatment benefits is unclear. Characteristics of the intervention protocol were not reported consistently across studies.

Uncertainty persists about whether whole-body vibration therapy can be a distinctive therapy for the prevention and treatment of osteoporosis, or whether it should be used as an adjunctive therapy. A few studies evaluated whole-body vibration as an adjunctive therapy; two studies examined whole-body vibration along with an exercise program,27,57 and one study examined whole-body vibration along with drug therapy.31 A few studies required participants to have adequate nutritional intake in order to be included,21,27 and some studies either provided Vitamin D and/or calcium or advised participants about appropriate levels of these nutrients.27,31,47,52,57 This raises an important question as to whether whole-body vibration therapy can be considered as a distinct treatment or whether it should be used in addition to other osteoporosis therapies. Several key informants indicated that whole-body vibration therapy should not replace but instead be used in addition to other osteoporosis therapies.

The length of followup was relatively short in the scientific studies reviewed for this report, and little is known about whether any benefits from whole-body vibration therapy will persist over time, or about potential long-term side effects or harms. Studies used many different outcome measures to evaluate the benefits of whole-body vibration therapy. Most studies measured BMD as the bone outcome of interest,21,27,30-32,47,52,57,70,72,73 but some studies also measured other bone outcomes such as bone mineral content, fractures, and bone turnover markers.30-32,47,57,71,72 Studies also evaluated other outcomes such as balance, falls, mobility, postural control, and muscle strength.21,27,31,32,47,52,57,71,72 Several key informants indicated that fractures are the ideal outcome of interest, in addition to other bone outcomes. Many of them also suggested that additional outcomes, such as muscle strength and balance, may be valuable to measure because they could be particularly important for preventing fractures and falls. However, key informants pointed out that assessing rare outcomes such as fractures requires a large number of participants and long followup period. They also indicated that most bone outcomes occur slowly, so, observing significant changes may require long followup periods. The type of measurement technique chosen for studies may also influence whether significant changes in bone outcomes are observed. For instance, peripheral quantitative computed tomography (pQCT) measures volumetric BMD, whereas DXA measures areal BMD. pQCT may be more accurate and offer more diagnostic information than DXA.74 Therefore, consideration of measurement technique is important when evaluating bone outcomes.

Compliance and access to whole-body vibration therapy must also be considered when analyzing the potential benefits for the prevention and treatment of osteoporosis. Whole-body vibration platforms are available in therapeutic or clinical settings and can also be purchased by consumers for home use. Studies that installed whole-body vibration platforms in the participants’ home required them to use the platforms 7 days per week,30,47,71 while studies that had participants use the platform at a research or clinical facility required them to attend sessions 1-5 days per week.21,27,31,32,52,57,70,72,73 Both the site and the frequency of sessions may affect long-term compliance. Studies that measured compliance found a wide range, raising questions about long-term adherence for various treatment protocols. Additionally, the site and frequency of sessions may affect access to this therapy. Currently, third-party payers do not cover whole-body vibration devices, so consumers must pay out-of-pocket to purchase a platform for their home or to use a platform in a clinical setting. The out-of-pocket costs may affect whether, where, and how often a consumer uses a whole-body vibration platform.

A number of safety issues for consumers, including safety features available on the devices and the use of direct-to-consumer advertising, must also be considered. Individuals using whole-body vibration therapy may be at risk of falls whether from balance problems or disorientation during platform use. They may also experience other side effects while using the platform, such as decreased blood pressure. It is not clear that all whole-body vibration platforms used for osteoporosis have safety features, such as handrails, to address these issues. Nor do we know the potential long-term harms from using whole-body vibration therapy. Direct-to-consumer marketing for whole-body vibration platforms raises specific concerns, as well. Some key informants suggested that consumers may not be able to clearly distinguish low-intensity platforms intended for osteoporosis therapy from platforms intended for high intensity exercise.