# References

1 U.S. Department of Health and Human Services Public Health Office of the Surgeon General. Bone Health and Osteoporosis: A report of the Surgeon General. Rockville, MD. October. 14. 2004.
2 Looker AC, Melton LJ 3rd, Harris TB, et al. Prevalence and trends in low femur bone density among older US adults: NHANES 2005-2006 compared with NHANES III. Journal of Bone & Mineral Research. Jan. 2010;25(1):64-71. [pmid: 19580459].
3 Lippuner K, Golder M, Greiner R. Epidemiology and direct medical costs of osteoporotic fractures in men and women in Switzerland. Osteoporos Int. Mar. 2005;16(Suppl 2):S8-S17. [pmid: 15378232].
4 Belavy DL, Miokovic T, Armbrecht G, et al. Resistive vibration exercise reduces lower limb muscle atrophy during 56-day bed-rest. Journal of Musculoskeletal Neuronal Interactions. Oct-Dec. 2009;9(4):225-35. [pmid: 19949280].
5 Screening for Osteoporosis: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2011. Jan. 17.
6 Compston J, Cooper A, Cooper C, et al. Guidelines for the diagnosis and management of osteoporosis in postmenopausal women and men from the age of 50 years in the UK. Maturitas. Feb. 20. 2009;62(2):105-8. [pmid: 19135323].
7 Qaseem A, Snow V, Shekelle P, et al. Pharmacologic treatment of low bone density or osteoporosis to prevent fractures: a clinical practice guideline from the American College of Physicians. Ann Intern Med. Sep. 16. 2008;149(6):404-15. [pmid: 18794560].
8 Watts NB, Lewiecki EM, Miller PD, et al. National Osteoporosis Foundation 2008 Clinician’s Guide to Prevention and Treatment of Osteoporosis and the World Health Organization Fracture Risk Assessment Tool (FRAX): what they mean to the bone densitometrist and bone technologist, J Clin Densitom. Oct-Dec. 2008;11(4):473-7.
9 Kanis JA, Burlet N, Cooper C, et al. European guidance for the diagnosis and management of osteoporosis in postmenopausal women. Osteoporos Int. Apr. 2008;19(4):399-428. [pmid: 18266020].
10 Hamdy RC, Baim S, Broy SB, et al. Algorithm for the management of osteoporosis. Southern Medical Journal. Oct. 2010;103(10):1009-15. quiz 16. [pmid: 20818296].
11 LaFleur J, McAdam-Marx C, Kirkness C, et al. Clinical risk factors for fracture in postmenopausal osteoporotic women: a review of the recent literature. Ann Pharmacother. Mar. 2008;42(3):375-86. [pmid: 18230704].
12 Shane E, Burr D, Ebeling PR, et al. Atypical subtrochanteric and diaphyseal femoral fractures: report of a task force of the American Society for Bone and Mineral Research. Journal of Bone & Mineral Research. Nov. 2010;25(11):2267-94. [pmid: 20842676].
13 van Duijnhoven NTL, Thijssen DHJ, Green DJ, et al. Resistive exercise versus resistive vibration exercise to counteract vascular adaptations to bed rest. Journal of Applied Physiology. Jan. 2010;108(1):28-33. [pmid: 19875710].
14 Bruyere O, Burlet N, Delmas PD, et al. Evaluation of symptomatic slow-acting drugs in osteoarthritis using the GRADE system. BMC Musculoskeletal Disorders. 2008;9:165. [pmid: 19087296].
15 Taggart H, Bolognese MA, Lindsay R, et al. Upper gastrointestinal tract safety of risedronate: a pooled analysis of 9 clinical trials. Mayo Clin Proc. Mar. 2002;77(3):262-70. [pmid: 11888030].
16 Kim SY, Kim MJ, Cadarette SM, et al. Bisphosphonates and risk of atrial fibrillation: a meta-analysis. Arthritis Res Ther. 2010;12(1):R30. [pmid: 20170505].
17 Green J, Czanner G, Reeves G, et al. Oral bisphosphonates and risk of cancer of oesophagus, stomach, and colorectum: case-control analysis within a UK primary care cohort. BMJ. 2010;341:c4444. [pmid: 20813820].
18 Lewis RD, Modlesky CM. Nutrition, physical activity, and bone health in women. Int J Sport Nutr. Sep. 1998;8(3):250-84. [pmid: 9738135].
19 Rizzoli R, Bianchi ML, Garabedian M, et al. Maximizing bone mineral mass gain during growth for the prevention of fractures in the adolescents and the elderly. Bone. Feb. 2010;46(2):294-305. [pmid: 19840876].
20 Lim LS, Hoeksema LJ, Sherin K. Screening for osteoporosis in the adult U.S. population: ACPM position statement on preventive practice. Am J Prev Med. Apr. 2009;36(4):366-75. [pmid: 19285200].
21 Gusi N, Raimundo A, Leal A. Low-frequency vibratory exercise reduces the risk of bone fracture more than walking: a randomized controlled trial. BMC Musculoskeletal Disorders. 2006;7:92. [pmid: 17137514].
22 Cardinale M, Pope MH. The effects of whole body vibration on humans: dangerous or advantageous?. Acta Physiologica Hungarica. 2003;90(3):195-206. [pmid: 14594190].
23 Cardinale M, Rittweger J. Vibration exercise makes your muscles and bones stronger: fact or fiction?. J Br Menopause Soc. Mar. 2006;12(1):12-8. [pmid: 16513017].
24 Cardinale M, Wakeling J. Whole body vibration exercise: are vibrations good for you?. British Journal of Sports Medicine. Sep. 2005;39(9):585-9. discussion 9. [pmid: 16118292].
25 Eisman JA. Good, good, good... good vibrations: the best option for better bones?. Lancet. Dec. 8. 2001;358(9297):1924-5. [pmid: 11747912].
26 Rubin C, Xu G, Judex S. The anabolic activity of bone tissue, suppressed by disuse, is normalized by brief exposure to extremely low-magnitude mechanical stimuli. FASEB J. Oct. 2001;15(12):2225-9. [pmid: 11641249].
27 von Stengel S, Kemmler W, Engelke K, et al. Effects of whole body vibration on bone mineral density and falls: results of the randomized controlled ELVIS study with postmenopausal women. Osteoporos Int. 2010. Mar. 20.
28 Slatkovska L, Alibhai SM, Beyene J, et al. Effect of whole-body vibration on BMD: a systematic review and meta-analysis. Osteoporos Int. 2010. Apr. 21.
29 Torvinen S, Kannus P, Sievanen H, et al. Effect of 8-month vertical whole body vibration on bone, muscle performance, and body balance: a randomized controlled study. Journal of Bone & Mineral Research. May. 2003;18(5):876-84. [pmid: 12733727].
30 Rubin C, Recker R, Cullen D, et al. Prevention of postmenopausal bone loss by a low-magnitude, high-frequency mechanical stimuli: a clinical trial assessing compliance, efficacy, and safety. Journal of Bone & Mineral Research. Mar. 2004;19(3):343-51. [pmid: 15040821].
31 Iwamoto J, Takeda T, Sato Y, et al. Effect of whole-body vibration exercise on lumbar bone mineral density, bone turnover, and chronic back pain in post-menopausal osteoporotic women treated with alendronate. Aging Clin Exp Res. Apr. 2005;17(2):157-63. [pmid: 15977465].
32 Verschueren SMP, Roelants M, Delecluse C, et al. Effect of 6-month whole body vibration training on hip density, muscle strength, and postural control in postmenopausal women: a randomized controlled pilot study. Journal of Bone & Mineral Research. Mar. 2004;19(3):352-9. [pmid: 15040822].
33 Rittweger J. Vibration as an exercise modality: how it may work, and what its potential might be. European Journal of Applied Physiology. Mar. 2010;108(5):877-904. [pmid: 20012646].
34 Nokes LD, Thorne GC. Vibrations in orthopedics. Crit Rev Biomed Eng. 1988;15(4):309-49. [pmid: 3286115].
35 Prisby RD, Lafage-Proust M-H, Malaval L, et al. Effects of whole body vibration on the skeleton and other organ systems in man and animal models: what we know and what we need to know. Ageing Research Reviews. Dec. 2008;7(4):319-29. [pmid: 18762281].
36 Rauch F. Vibration therapy. Developmental Medicine & Child Neurology. Oct. 2009;51(Suppl 4):166-8. [pmid: 19740225].
37 Totosy de Zepetnek JO, Giangregorio LM, Craven BC. Whole-body vibration as potential intervention for people with low bone mineral density and osteoporosis: a review. Journal of Rehabilitation Research & Development. 2009;46(4):529-42. [pmid: 19882487].
38 Rauch F, Sievanen H, Boonen S, et al. Reporting whole-body vibration intervention studies: recommendations of the International Society of Musculoskeletal and Neuronal Interactions. J Musculoskelet Neuronal Interact. Sep. 2010;10(3):193-8. [pmid: 20811143].
39 Flinn ED. Subtle shake-up in bone-loss research. Aerospace America. Mar. 2002;40(3):16-8. [pmid: 11898823].
40 Rubin C, Pope M, Fritton JC, et al. Transmissibility of 15-hertz to 35-hertz vibrations to the human hip and lumbar spine: determining the physiologic feasibility of delivering low-level anabolic mechanical stimuli to skeletal regions at greatest risk of fracture because of osteoporosis. Spine (Phila Pa 1976). Dec. 1. 2003;28(23):2621-7. [pmid: 14652479].
41 Xie L, Jacobson JM, Choi ES, et al. Low-level mechanical vibrations can influence bone resorption and bone formation in the growing skeleton. Bone. Nov. 2006;39(5):1059-66. [pmid: 16824816].
42 Judex S, Lei X, Han D, et al. Low-magnitude mechanical signals that stimulate bone formation in the ovariectomized rat are dependent on the applied frequency but not on the strain magnitude. J Biomech. 2007;40(6):1333-9. [pmid: 16814792].
43 Xie L, Rubin C, Judex S. Enhancement of the adolescent murine musculoskeletal system using low-level mechanical vibrations. Journal of Applied Physiology. Apr. 2008;104(4):1056-62. [pmid: 18258802].
44 Bosco C, Iacovelli M, Tsarpela O, et al. Hormonal responses to whole-body vibration in men. European Journal of Applied Physiology. Apr. 2000;81(6):449-54. [pmid: 10774867].
45 Erskine J, Smillie I, Leiper J, et al. Neuromuscular and hormonal responses to a single session of whole body vibration exercise in healthy young men. Clinical Physiology & Functional Imaging. Jul. 2007;27(4):242-8. [pmid: 17564674].
46 Fritton JC, Rubin CT, Qin YX, et al. Whole-body vibration in the skeleton: development of a resonance-based testing device. Annals of Biomedical Engineering. Sep-Oct. 1997;25(5):831-9. [pmid: 9300107].
47 Gilsanz V, Wren TAL, Sanchez M, et al. Low-level, high-frequency mechanical signals enhance musculoskeletal development of young women with low BMD. Journal of Bone & Mineral Research. Sep. 2006;21(9):1464-74. [pmid: 16939405].
48 Cardinale M, Lim J. Electromyography Activity of Vastus Lateralis Muscle During Whole-Body Vibrations of Different Frequencies. Journal of Strength & Conditioning Research. 2003;17(3):621-4. [pmid: 12930196].
49 Hazell TJ, Kenno K, Jakobi JM. Evaluation of muscle activity for loaded and unloaded dynamic squats during vertical whole-body vibration. Journal of Strength & Conditioning Research. 2010;24(7):1860-5. [pmid: 20543737].
50 Roelants M, Verschueren S, Delecluse C, et al. Whole-Body-Vibration-Induced Increase In Leg Muscle Activity During Different Squat Exercises. Journal of Strength & Conditioning Research. 2006;20(1):124-9. [pmid: 16503671].
51 Pollack R, Woledge R, Mills K, et al. Muscle activity and acceleration during whole body vibration: Effect of frequency and amplitude. Clin Biomech. 2010;25(8):840-6.
52 Russo CR, Lauretani F, Bandinelli S, et al. High-frequency vibration training increases muscle power in postmenopausal women. Archives of Physical Medicine & Rehabilitation. Dec. 2003;84(12):1854-7. [pmid: 14669194].
53 Torvinen S, Kannu P, Sievanen H, et al. Effect of a vibration exposure on muscular performance and body balance. Randomized cross-over study. Clinical Physiology & Functional Imaging. Mar. 2002;22(2):145-52. [pmid: 12005157].
54 Ward K, Alsop C, Caulton J, et al. Low magnitude mechanical loading is osteogenic in children with disabling conditions. Journal of Bone & Mineral Research. Mar. 2004;19(3):360-9. [pmid: 15040823].
55 Tanaka SM, Alam IM, Turner CH. Stochastic resonance in osteogenic response to mechanical loading. FASEB J. Feb. 2003;17(2):313-4. [pmid: 12475888].
56 Kerschan-Schindl K, Grampp S, Henk C, et al. Whole-body vibration exercise leads to alterations in muscle blood volume. Clinical Physiology. 2001;21(3):377-82. [pmid: 11380538].
57 Bemben DA, Palmer IJ, Bemben MG, et al. Effects of combined whole-body vibration and resistance training on muscular strength and bone metabolism in. Bone. 2010;47(3):650-6. [pmid: 20601282].
58 Ezenwa B, Yeoh HT. Multiple vibration displacements at multiple vibration frequencies stress impact on human femur computational analysis. Journal of Rehabilitation Research & Development. 2011;48(2):179-90. [pmid: 21480091].
59 Bobba RS, Beattie K, Parkinson B, et al. Tolerability of different dosing regimens of bisphosphonates for the treatment of osteoporosis and malignant bone disease. Drug Saf. 2006;29(12):1133-52. [pmid: 17147460].
60 Cramer JA, Gold DT, Silverman SL, et al. A systematic review of persistence and compliance with bisphosphonates for osteoporosis. Osteoporos Int. Aug. 2007;18(8):1023-31. [pmid: 17308956].
61 Lings S, Leboeuf-Yde C. Whole-body vibration and low back pain: a systematic, critical review of the epidemiological literature 1992-1999. International Archives of Occupational & Environmental Health. Jul. 2000;73(5):290-7. [pmid: 10963411].
62 Tiemessen IJ, Hulshof CT, Frings-Dresen MH. Low back pain in drivers exposed to whole body vibration: analysis of a dose-response pattern. Occup Environ Med. Oct. 2008;65(10):667-75. [pmid: 18216125].
63 Walker-Bone K, Palmer KT. Musculoskeletal disorders in farmers and farm workers. Occup Med (Lond). Dec. 2002;52(8):441-50. [pmid: 12488514].
64 Matoba T. Cardiovascular reactions to vibration stress. J UOEH. Mar. 20. 1989;11(Suppl):96-105. [pmid: 2664959].
65 Seidel H, Harazin B, Pavlas K, et al. Isolated and combined effects of prolonged exposures to noise and whole-body vibration on hearing, vision and strain. International Archives of Occupational & Environmental Health. 1988;61(1-2):95-106. [pmid: 3198289].
66 Dandanell R, Engstrom K. Vibration from riveting tools in the frequency range 6 Hz-10 MHz and Raynaud’s phenomenon. Scand J Work Environ Health. Aug. 1986;12(4 Spec No):338-42. [pmid: 3775319].
67 Kiiski J, Heinonen A, Järvinen TL, et al. Transmission of vertical whole body vibration to the human body. Journal of bone and mineral research : the official journal of the American Society for Bone and Mineral Research. 2008;23(8):1318-25.
68 Abercromby AF, Amonette WE, Layne CS, et al. Vibration exposure and biodynamic responses during whole-body vibration training. Medicine & Science in Sports & Exercise. Oct. 2007;39(10):1794-800. [pmid: 17909407].
69 Vela JI, Andreu D, Diaz-Cascajosa J, et al. Intraocular lens dislocation after whole-body vibration. J Cataract Refract Surg. Oct. 2010;36(10):1790-1. [pmid: 20870128].
70 Ruan X-Y, Jin F-Y, Liu Y-L, et al. Effects of vibration therapy on bone mineral density in postmenopausal women with osteoporosis. Chinese Medical Journal. Jul. 5. 2008;121(13):1155-8. [pmid: 18710630].
71 Semler O, Fricke O, Vezyroglou K, et al. Results of a prospective pilot trial on mobility after whole body vibration in children and adolescents with osteogenesis imperfecta. Clinical Rehabilitation. May. 2008;22(5):387-94. [pmid: 18441035].
72 Pitukcheewanont P, Safani D. Extremely Low-Level, Short-Term Mechanical Stimulation Increases Cancellous and Cortical Bone Density and Muscle Mass of Children With Low Bone Density: A Pilot Study. Endocrinologist. 2006;16(3):128-32.
73 Ezenwa B, Burns E, Wilson C. Multiple vibration intensities and frequencies for bone mineral density improvement. Paper presented at: Conference Proceedings: Annual International Conference of the IEEE Engineering in Medicine & Biology Society. 2008.
74 Ito M, Tsurusaki K, Hayashi K. Peripheral QCT for the Diagnosis of Osteoporosis. Osteoporosis International. 1997;7(Suppl 3):S120-S7. [pmid: 9536317].
75 World Health Organization. Assessment of Fracture Risk and Its Application to Screening for Postmenopausal Osteoporosis, WHO Technical Report Series. 1994;843.