# Next Steps

Whole-body vibration therapy for the prevention and treatment of osteoporosis is still investigational with little known about benefits and harms. Further research is needed to fully understand what role this therapy should have. Since bone outcomes take a long time to show clinical changes and fractures are rare events, randomized controlled trials would require longer followup periods. The length of followup required will vary depending on the outcomes of interest and measurement techniques used to assess outcomes, but studies should followup for a minimum of one year and for up to several years for rare outcomes. Multiple outcomes would need evaluation, including measures of bone and muscle, fractures, balance, and quality of life, because these outcomes may be closely related to osteoporosis. A thorough understanding of measurement issues for bone outcomes (e.g., pQCT versus DXA) would be useful. Harms should be systematically collected and reported along with the outcomes of interest. Studies need to focus on the population groups that could benefit from whole-body vibration (e.g., individuals with osteoporosis, individuals with low BMD, or individuals at risk for osteoporosis or low BMD), and individuals at risk for harms, such as those with certain health conditions. In future studies with a large number of participants, studies should focus on benefits and harms for individuals with different risks for osteoporosis and severity of the disease. Studies should also focus on the optimal treatment protocol to achieve benefits for the prevention and treatment of osteoporosis, including the platform type, platform settings (frequency, amplitude, acceleration), session length, and session frequency. Additionally, studies should focus on whether it is optimal for the platform settings to change during a session or during the intervention. Further research could also address the issues of whole-body vibration as an adjunctive versus a distinctive therapy, and treatment compliance for the populations of interest.

Studies need to consistently report all aspects of the treatment protocol. Additional aspects of the study and treatment protocol should be specified, including whether participants had adequate nutritional intake, completed therapy sessions at home or in a supervised clinical/research setting, flexed their knees while on the platform, performed dynamic exercises during the vibration session, wore specific footwear while on the platform, and whether the platforms had safety features or automatically calibrated settings to an individual’s weight. Studies might also assess the actual vibration intensity transmitted to the study participants.

We use the PICO framework to present research recommendations that would provide information important to clinicians, consumers, and policymakers.

- Study type. RCTs with long followup period. Because the followup period may vary depending on the outcomes of interest and measurement technique, a minimum of one year is needed.
- Populations. Individuals that could benefit from whole-body vibration therapy (individuals with osteoporosis or low BMD or individuals at risk for osteoporosis or low BMD), which includes individuals who cannot or do not want to follow drug or exercise regimens, and individuals that could experience harms from whole-body vibration therapy. Subgroups with differing risks for osteoporotic fracture, severity of osteoporosis, and contraindications to other preventative treatments.
- Intervention protocol. Platform type, platform settings (frequency, amplitude, acceleration), session lengths, session frequency, changes in platform settings, adjunctive versus distinctive therapy.
- Comparator. Pharmacological treatments or exercise and diet programs, including direct comparisons as distinctive treatments and comparisons as adjunctive treatments. Noninferiority studies with pharmacological treatment for patients who cannot tolerate such treatment or prefer nonpharmacological treatment options.
- Outcomes. Bone outcomes such as BMD and fractures, muscle outcomes such as muscle strength, balance, quality of life, and systematic reporting of harms.
- Additional considerations. Compliance, nutritional intake, location of therapy, posture/knee flexion, whether dynamic exercises are performed, safety features, the actual transmission of vibration from the platform to different parts of the body and skeletal region.

Several ongoing or completed clinical trials are examining whole-body vibration therapy for osteoporosis (NCT00420940; NCT00396994; NCT00667667). These studies will add to the literature and may offer more insight into the use of this therapy.

In addition to more research, clear information should be made available to consumers about the correct whole-body vibration devices for the prevention and treatment of osteoporosis. Since certain levels of vibration are harmful, particularly for the population using these platforms for osteoporosis rather than for high intensity exercise, consumers need access to educational material about different whole-body vibration platforms available to them in clinical settings, rehabilitation facilities, exercise facilities, and for home use. Consumers also need information about the correct settings, session length, and session frequency to achieve benefits. Finally, potential consumers need to know about the benefits and harms of all treatments available to them.