# Methods

We integrated information from key informants and the literature review to address the guiding questions. In particular, responses to questions 1, 2, and 4 relied on information from key informants and published information about vibration technology, the applications of the technology, and the FDA approval process. Responses to question 3 were based on peer-reviewed published studies that examined bone outcomes after whole-body vibration therapy for osteoporosis.

## Discussion With Key Informants

We identified relevant key informants for this technical brief with the goals of efficient data collection and balanced viewpoints. We included osteoporosis experts, whole-body vibration experts, practicing clinicians who use whole-body vibration, consumer advocates, and potential consumers. We also included several representatives from different whole-body vibration platform manufacturers to get diverse perspectives from device producers. We located key informants from frequently listed and cited authors of relevant literature, Internet searches for possible candidates of relevant viewpoints, and nominations by other key informants. In cases where we were not able to identify a specific individual to represent a specific organization, we invited the organization to nominate an individual. In some cases, key informants with a viewpoint or expertise critical to this report had a conflict of interest, so we interviewed them separately from other key informants to avoid undue influence.

We conducted semi-structured interviews with key informants via telephone or in person during December 2010. Interview guides for each group of key informants were developed in advance. The guides are presented in Appendix B.

## Grey Literature Search

We conducted a grey literature search of Federal Government Web sites (e.g., www.medicare.gov) for current coverage and/or payment policies, the FDA Web site for approval reviews, and presentations of unpublished studies at scientific meetings. We also searched the Internet with different engines (e.g., Google Scholar, Scirus, LexisNexis) to obtain information on availability and other issues and controversies regarding vibration platforms. We surveyed enrolling and ongoing clinical trials though the ClinicalTrials.gov Web site. We also searched the CSA Physical Education Index, the Web of Science^®^, and Medscape^®^ databases to find studies that were presented in scientific meetings.

## Published Literature Search

For Question 3 we searched for relevant articles on the use of whole-body vibration for the prevention and treatment of osteoporosis and for patients with low bone density. We searched several databases: MEDLINE^®^ via OVID and via PubMed^®^, the Cochrane Library, AMED, CINAHL, the CSA Physical Education Index, the Web of Science, PEDro, and Academic Search^™^ Premier. Exact search strategies were developed in consultation with the EPC librarian and guided by the Scientific Resource Center. We developed an a priori search strategy based on relevant medical subject headings (MeSH) terms, text words, and a weighted word-frequency algorithm to identify related articles. The search strategy is shown in Appendix C.

We screened the abstracts against the following exclusion criteria:

1. Animal studies.
2. Studies examining healthy adults and children without low bone mineral density or risk for osteoporosis.
3. Studies examining patients with other primary conditions such as cerebral palsy, Parkinson’s disease, multiple sclerosis, cystic fibrosis, and spinal cord injuries because it is unknown whether these populations may have safety concerns that are different than for other individuals at risk for or with osteoporosis.
4. Studies on whole-body vibration as an exercise modality with no clinical bone measures reported.
5. Market evaluations of whole-body vibration platforms.

We included studies published in English of any sample size, any design (randomized controlled trials (RCTs), controlled clinical trials, uncontrolled observational trials, and case reports and series) and studies that report any clinical bone outcome (e.g., bone density, bone mineral content, bone fractures). We retrieved and reviewed full articles on eligible studies to determine final inclusion.