# Guiding Questions

The questions below guided the data collection for this technical brief. Question 1 examines whole-body vibration in the context of other treatments for osteoporosis. Question 2 provides background on the use of whole-body vibration for osteoporosis in the United States. Results for Questions 1 and 2 are reported in the Findings section, “Description of Existing Whole-body Vibration Technology.” Question 3 examines the current evidence of vibration therapy for osteoporosis; we describe the populations included in studies, the detailed components of the platforms and treatment protocols, and the outcomes and harms measured. Results for this question are reported under Added Evidence Map in the Findings section. Issues of importance to different stakeholders and key areas for future research (question 4) are addressed in the “Summary and Implications” section.

1. Describe the existing technology.
  a. What vibration modalities have been proposed or used in practice to treat osteoporosis?
  b. What are the potential advantages and disadvantages of vibration therapy when compared to regular exercise and pharmacological treatments of osteoporosis in preventing osteoporotic fractures?
  c. What are the potential safety issues and harms of vibration therapy when used to treat osteoporosis?
2. Describe the context in which the technology is used.
  a. What kinds of training, certification, and staffing are required for vibration therapy?
  b. How are treatment sessions in clinical settings billed?
  c. What is the current U.S. Food and Drug Administration (FDA) approval status of vibration therapy for osteoporosis?
  d. What modifications of vibration platforms are in development?
3. Describe the current evidence of the technology.
  a. What are the inclusion and exclusion criteria of patients in therapeutic studies of vibration therapy for osteoporosis?
  b. What modalities of vibration therapy for osteoporosis have been examined in therapeutic studies?
  c. What was the length, intensity, and frequency of each vibration therapy session, and what was the total duration of the vibration therapy intervention?
  d. What primary and secondary outcomes and harms were examined?
  e. What comparators were used to examine benefits and harms?
  f. What was the length of followup to examine benefits and harms?
  g. What were the methodological approaches or study designs used (i.e., randomized controlled trial, cohort, case control, etc.)?
4. Identify the important issues raised by the technology.
  a. What are the implications of reimbursement practices on accessibility?
  b. What are the possible areas of confusion or potential harms from misuse in direct-to-consumer marketing and unsupervised consumer use?
  c. What medical claims about effectiveness have been made, and how do they compare to what is available in the literature? What are the implications for third-party payers?
  d. What are possible areas of future research?