# Appendixes

Appendix A Definition of Terms

Appendix B Interview Guides for Key Informants

Appendix C Published Literature Search Strategy

Appendix D Example of Whole-Body Vibration Platform

Appendix E Evidence Tables