# Evidence Tables

Evidence Table 1 Patient populations

Author, Year Country, Study Design | Inclusion Criteria | Exclusion Criteria | Presence of Men | Presence of Minorities | Comorbidities | Prior Treatments for Osteoporosis
Gusi, 2006^21^ Spain RCT | Women; At least 5 years from last menstruation; adequate nutritional status according to World Health Organization (determined by questionnaire); Non-smoker; Consumption of no more than 4 alcoholic beverages per week; The ability to follow the protocol; Free from disease or medication known to affect bone metabolism or muscle strength | Acute hernia; Thrombosis; Any pharmacologic intervention for osteopenia within the previous 6 months; Any history of severe musculoskeletal problems; Engaged in high-impact activity at least twice a week (any weight-bearing activity or exercise more intense than brisk walking) | No | Not reported | Not reported | Individuals excluded who had any pharmacologic intervention for osteopenia within previous 6 months; Individuals excluded who engaged in high-impact exercise more than 2 times per week; Unknown diet/calcium intake
Ruan, 2008^70^ China CT | Women with osteoporosis; Postmenopausal women without typical menopausal symptoms; No older than 80 years old; Women willing to participate as volunteers | Women with blood pressure higher than 160/110 mmHg on medication; Women with systolic blood pressure less than 90 mmHg; Women with heart disease or cerebrovascular disease; Women with epileptics; Women with thrombosis or a history of thrombosis within the past 6 months; Women with body implants or heart stents; Women with lumbar disc herniation or spondylolisthesis, spinal nerve canal stenosis or oppression; Women in poor health and with symptoms of imbalance or vertigo; Women on treatment with drugs for osteoporosis or other agents affecting bone metabolism; Women unrecovered from surgical operations; Women un-recovered from joint injuries, fractures, or muscle strain | No | Not reported | Not reported | Women excluded who were taking drugs for osteoporosis or other agents affecting bone metabolism; Unknown physical activity levels apart from intervention; Unknown diet/calcium intake
Semler, 2008^71^ Germany Case series | Motor-impaired children with osteogenesis imperfecta | NA | Yes | Not reported | Not reported | Yes - bisphosphonates; Unknown diet/calcium intake
Bemben, 2010^57^ US CT | Healthy women volunteers, 55-75 years of age; Subjects who were at least 5 years postmenopausal; Subjects who were not taking hormone replacement therapy (HRT); Previous HRT users had not taken HRT for at least 1 year; Subjects who had not participated in a weight training program for at least 1 year prior to the study; Subjects who were medically stable, ambulatory, and capable of undergoing physical strength testing and training; Subjects who were of a mental capacity to give written informed consent and comply with the protocols | Women with diagnosed osteoporosis or a BMD site with a T-score less than -2.5; Women with physical disabilities preventing them from being strength tested and trained, including orthopedic or arthritic problems; Women with heart problems such as congestive heart failure and arrhythmias, chronic high blood pressure, or those on Beta Blockers; Current smokers or past smokers within the previous 15 years; Women with current diagnosis or a history of renal disease, chronic digestive or eating disorders, rheumatoid arthritis, or uncontrolled thyroid disease; Women taking medications that affect bone density, such as steroid hormones, calcitonin, or corticosteroids; Women taking medications for osteoporosis treatment, including biophosphonates, selective estrogen receptor modulators, or parathyroid hormone | No | Not reported | Not reported | Women with osteoporosis were excluded; Women excluded who were taking medications that affect bone density or medications for osteoporosis treatment (bisphosphonates, selective estrogen receptor modulators, or parathyroid hormone); Baseline calcium and physical activity recorded
Verschueren, 2004^32^ Belgium RCT | Women 60-70 years of age; Noninstitutionalized; Free from diseases or medications known to affect bone metabolism or muscle strength | Women with total body BMD t-score of less than -2.5 | No | Not reported | Not reported | Women with osteoporosis excluded; women excluded who were taking medications that affect bone metabolism; Unknown prior exercise; Unknown diet/calcium intake
von Stengel, 2010^27^ Germany RCT | Postmenopausal women aged 65 years and older living independently in the community in Germany were contacted by mail (mailing lists were obtained from the Siemans Health Insurance Company database) | Diseases or medication affecting bone metabolism; Diseases or medication affecting neuromuscular performance and falls; Implants of the lower extremity or of the spine; Eye diseases affecting the retina; Low physical capacity (<50 W) | No | Not reported | Not reported | Individuals excluded who were taking medication affecting bone metabolism; Baseline calcium, vitamin D, and physical activity recorded
Rubin, 2004^30^ US RCT | Normal nutritional status (as determined by questionnaire); Stable weight maintenance (i.e., no elective weight loss or diet); Estimated daily calcium intake of ≥500 mg/day; Capability of following the protocol for daily use of the device as well as understanding and providing informed consent; Body mass greater than 45 kg and less than 84 kg (due to design constraints of the oscillating device) | Any pharmacologic intervention for osteopenia within the previous 6 months; Any use of steroids; Current smoking status; Consumption of excessive alcohol (>2 drinks/day), evidence of osteomalacia; Paget’s disease; Osteogenesis imperfecta; Gastrointestinal disease; History of malignancy; Prolonged immobilization of the axial or appendicular skeleton within the last 3 years | No | Not reported | Not reported | Individuals excluded who had any pharmacologic intervention for osteopenia within previous 6 months; Unknown prior exercise; Minimum calcium intake required for participation
Russo, 2003^52^ Italy RCT | Women belonging to a hospital volunteers association; Women at least 1 year postmenopausal; Women not affected by conditions that contraindicated the vibration training; Women on hormone replacement therapy were considered eligible | Women with metabolic bone disorders | No | Not reported | Not reported | Not reported; Minimum calcium and vitamin D intake required for participation
Iwamoto, 2005^31^ Japan RCT | Post-menopausal women, aged 55-88, with osteoporosis (in Japan this means patients whose BMD t-score was <70 or 70-80% with a history of osteoporotic fractures) who were patients at the hospital in Japan; Chronic back pain that did not require bed-rest treatment; No subjects had a history of HRT or had ever taken medication that affects bone metabolism prior to this study; No subjects had taken medication such as nonsteroid anti-inflammatory drugs to relieve chronic back pain; All were instructed to take 800 mg of calcium daily in food | Patients with osteoarthritis of the knee; Patients with moderate to severe spondylosis or degenerative disc disease of the thoracic and lumbar spine; Patients with musculo-skeletal diseases other than osteoporosis that cause back pain; Patients who had undergone arthroplasty of the knee or hip joint | No | Not reported | Not reported | No medications affecting bone metabolism prior to this study; all participants had low physical activity; Unknown diet/calcium intake
Gilsanz, 2006^47^ US CT | Healthy white females 15-20 years old who had previously sustained at least one fracture; Females who had completed puberty (Tanner stage V of sexual development); Out of the 150 candidates who matched these criteria, the 50 females with the lowest CT values for vertebral cancellous BMD (~1 SD below mean peak BMD values) were invited to participate in the intervention phase | Females who had a diagnosis of any underlying disease or chronic illness; Females who had been ill for >2 weeks during the previous 6 months; Females who had been admitted to the hospital at any time during the previous 3 years; Females who were taking any medications including oral contraceptives; Females who were pregnant, had ever been pregnant, or with an absence of menses for >4 consecutive months or two cycle lengths after establishing regular cycles; Females in whom the epiphyses of the phalanges and the metacarpels had not fused completely | No | No | No | No medications; Baseline physical activity and calcium intake recorded
Pitukcheewanont, 2006^72^ US Case series | Female children diagnosed with endocrine disorders of various etiologies and low bone density; Only children at Tanner stage I or II for sexual development were allowed to participate | Any medication known to affect bone density | No | Not reported | Not reported | No medications; Unknown exercise; Unknown diet/calcium intake
Ezenwa, 2008^73^ US Case series | At least 65-years old; Able to go from sitting to standing without assistance; Walk up and down 3 steps; Ambulate 50 feet with or without a cane and without exhibiting shortness of breath or chest pain | Any medical condition that might affect BMD (e.g., bone cancer, end-stage renal disease, long-term steroid use, etc.); Other neurological conditions affecting balance and strength (e.g., history of stroke, Parkinson’s disease, vertigo) | Yes | Not reported | Not reported | Not reported

Evidence Table 2 Vibration modalities

Author, Year Country | Setting | Living Arrangement of Participants | WBV Platform Type | Manufacturer
Gusi, 2006^21^ Spain | Clinic (Assumed) | Community | Side-alternating | Galileo 2000, Novotec, Germany
Ruan, 2008^70^ China | Clinic | Community (campus of Beijing Institute of Technology) | Synchronous | ZD-10, Beijing Maidakang Medical Equipment Company, China
Semler, 2008^71^ Germany | Home | Community | Side-alternating | Cologne Standing and Walking Trainer System Galileo (modified til-table combined with the Galileo whole body vibration system)
Bemben, 2010^57^ US | Clinic | Community | Triplanar | Power-Plate North America, Inc., Northbrook, Illinois
Verschueren, 2004^32^ Belgium | Clinic | Community | Not reported | PowerPlate, Amsterdam, The Netherlands
von Stengel, 2010^27^ Germany | Clinic & Home | Community | Synchronous | Vibrafit, Solms, Germany
Rubin, 2004^30^ US | Home | Community | Synchronous | Model LA18-18; BEI San Marcos, California
Russo, 2003^52^ Italy | Clinic | Community | Side-alternating | Galileo 2000
Iwamoto, 2005^31^ Japan | Clinic | Community | Side-alternating | Galileo, Novotec, Pforzheim, Germany
Gilsanz, 2006^47^ US | Home | Community | Synchronous | Not reported explicitly
Pitukcheewanont, 2006^72^ US | Clinic | Community | Synchronous | BEI model LA18-18; San Marcos, California
Ezenwa, 2008^73^ US | Clinic | Community | Not reported | Developed for study

Evidence Table 3 Vibration interventions I

Author, Year | WVB Intervention Frequency | WBV Intervention Amplitude | WBV Intervention Acceleration | WBV Intervention Session Length | WBV Intervention Session Rest Periods | Changes in Platform Settings During Session | Changes in Platform Settings During Intervention Period | Flex Knees While on Platform | Extend Lower Extremities
Gusi, 2006^21^ | 12.6 Hz | 3 mm (vertical amplitude) | Not reported | First 2 weeks 3 minutes, Last 6 weeks 6 minutes | Yes - 1 minute vibration, 1 minute rest | No | No | Yes | No
Ruan, 2008^70^ | 30 Hz | 5 mm (amplitude) | Not reported | 10 minutes | No | No | No | No | No
Semler, 2008^71^ | 15-25 Hz | 1-2 mm (amplitude) | Not reported | 9 minutes., 2 times per day | Yes - 3 minutes vibration, 3 minutes rest | Yes - changes in frequency | Yes - changes in frequency and tilting-angle | Yes | Yes - bend and straighten knees while on platform
Bemben, 2010^57^ | 30-40 Hz | 2-4 mm (peak to peak) | 2.16-2.8 g (acceleration magnitude) | 15-60 second sessions with 1-3 sets | Yes - 15 second rest between sets | No | Yes - changes in frequency, acceleration, session length, and sets | Yes - during certain exercises | Yes - during certain exercises
Verschueren, 2004^32^ | 35-40 Hz | 1.7-2.5 mm (amplitude) | 2.28-5.09 g (peak acceleration) | 30 minutes which included warming up and cooling down | Yes | No | Yes - changes in duration of session, number of series of one exercise, number of different exercises, amplitude, frequency, | Yes - during certain exercises | Yes
von Stengel, 2010^27^ | 25-35 Hz | 1.7 mm (amplitude) | Not reported | 6 minutes | Yes - 1 minute break with stretching between exercises | No | Yes - changes in frequency, exercise intensity | Yes - during certain exercises | Yes - during certain exercises
Rubin, 2004^30^ | 30 Hz | Not reported | 0.2 g (peak to peak) | 10 minutes, 2 times per day | Yes - at least 10 hours. between 2 daily sessions | No | No | No | No
Russo, 2003^52^ | 12-28 Hz | Not reported | 0.1-10 g (acceleration) | First 1 month 3 minutes, Last 5 months 6 minutes. | Yes - 1 or 2 minutes vibration (3 sets), 1 minute rest between | No | Yes - change in frequency, session length | Yes | No
Iwamoto, 2005^31^ | 20 Hz | 0.7-4.2 mm (upwards and downwards) | Not reported | 4 minutes | No | No | No | Yes | No
Gilsanz, 2006^47^ | 30 Hz | Not reported | 0.3 g (peak to peak) | 10 minutes | No | No | No | Not reported | No
Pitukcheewanont, 2006^72^ | 30 Hz | Not reported | 0.3 g (vertical acceleration) | 30 minutes | No | No | No | Not reported | No
Ezenwa, 2008^73^ | Not reported | Not reported | Not reported | 15 minutes, 2 times per session | Not reported | Yes – changes in frequency | No | Not reported | Not reported

Evidence Table 4 Vibration interventions II

Author, Year | Type of Footwear Worn on Platform | Support Device | Intervention Frequency | Intervention Duration (week) | Combination of Treatments | Concomitant Treatments for Osteoporosis | Calcium Supplementation | Length of Followup (week)
Gusi, 2006^21^ | Barefoot | Not reported | 3 days per week, at least 1 day of rest in between sessions | 32 | No - but WBV program included warm-up with 5 minutes bicycling and 5 minutes stretching | No medications at start | No | 32
Ruan, 2008^70^ | Not reported | Yes | 5 times per week | 24 | No | No bone medications at start | No | 24
Semler, 2008^71^ | Not reported | Yes - patients strapped to tilt-table | 7 days per week | 24 | No | Yes - medications and physiotherapy continued | No | 24
Bemben, 2010^57^ | Shoes while standing; also sat on platform | Not reported | 3 days per week | 32 | Yes - WBV (which included dynamic movements) and resistance training | No bone medications at start | No but instructed to increase calcium intake if less than 1500 mg/day | 32
Verschueren, 2004^32^ | Shoes | Not reported | 3 days per week, at least 1 day of rest in between sessions | 24 | No - but WBV program included exercise on platform, warm-up, cool-down | No bone medications at start | No | 24
von Stengel, 2010^27^ | Not reported | Unknown | 2 clinical, 2 home | 72 | Yes - WBV and training | No bone medications at start | Yes - to participants that needed it - 1500 mg calcium and 400 IE vitamin D | 72
Rubin, 2004^30^ | Unknown | Yes | 7 days per week | 48 | No | No bone medications at start | No | 48
Russo, 2003^52^ | Not reported | Not reported | 2 days per week | 24 | No | Not reported if medications taken | Yes - all participants received calcium and Vitamin D | 24
Iwamoto, 2005^31^ | Not reported | Not reported | 1 day per week | 48 | Yes - WBV and alendronate (5 mg daily) | Yes - medication | No but instructed to get 800 mg in food daily | 48
Gilsanz, 2006^47^ | Not reported | Not reported | 7 days per week | 48 | No | No medications at start | Yes - all participants took 500 mg tablet daily | 48
Pitukcheewanont, 2006^72^ | Not reported | Yes | 3 days per week | 8 | No | No bone medications at start | No | 8
Ezenwa, 2008^73^ | Not reported | Yes | 3 times per week | 20 | No | Not reported if medications taken | No | 20

Evidence Table 5 Vibration outcomes I

Author, Year | Measured Compliance | Comparators | N for Comparator (ITT) | N for Comparator (Completed) | Bone Mineral Density | Measure of Bone Mineral Density | Harms
Gusi, 2006^21^ | Yes – reported rate | Walking program training group | 18 | 14 | Yes | Dual-energy x-ray absorptiometry (DXA) | None reported
Ruan, 2008^70^ | Not reported | Control group (no program) | 50 | 43 | Yes | Dual-energy bone densitometers | None reported
Semler, 2008^71^ | Reported there was high compliance but did not report specific rate (may have been selfreport) | NA | NA | NA | No | NA | Yes – some patients reported itching after vibration session; one patient reported localized pain at the end of an intramedullary rod which had been dislocated prior to the vibration intervention; one patient dropped out of the study after dislocation of a telescopic rod (which had happened before in this patient)
Bemben, 2010^57^ | Yes – reported rate | Resistance training group and control group (no program) | Unknown | 22 Resistance TG; 12 Control | Yes | DXA | None reported
Verschueren, 2004^32^ | Not reported | Resistance training group and control group (no program) | 22; 23 | 22; 23 | Yes | DXA | None reported
von Stengel, 2010^27^ | Yes – reported rate | Exercise training group and wellness program control group | 50; 51 | 47; 48 | Yes | DXA | None reported
Rubin, 2004^30^ | Yes – reported rate and assessed outcomes by compliance | Placebo device control group | 37 | 28 | Yes | DXA | None reported
Russo, 2003^52^ | Yes – reported rate | Control group (no program) | 17 | 14 | Yes | Peripheral quantitative computed tomography device (pQCT) | Yes - transient lower leg itching and erythema in 6 of 17 patients; moderate knee pain in 2 overweight participants with preexisting knee osteoarthritis
Iwamoto, 2005^31^ | Not reported | Alendronate-only (bisphosphonate) control group | 25 | 25 | Yes | DXA | None reported
Gilsanz, 2006^47^ | Yes – reported rate and assessed outcomes by compliance | Control group (no program) | 25 | 24 | Yes | Computed tomography (CT); DXA | None reported
Pitukcheewanont, 2006^72^ | Yes – reported all participants completed study | NA | NA | NA | Yes | CT | None reported
Ezenwa, 2008^73^ | Not reported | NA | NA | NA | Yes | DXA | None reported

Evidence Table 6 Vibration outcomes II

Author, Year | Site of Bone Mineral Density Measure | Bone Mineral Content | Bone Mineral Content Measure | Fracture | Measure of Fracture | Quality of Life | Quality of Life Measure | Other Outcomes
Gusi, 2006^21^ | Right proximal femur (femoral neck, trochanter and Ward’s triangle); lumbar spine | No | NA | No | NA | No | NA | Balance; BMI
Ruan, 2008^70^ | Lumbar spine L2-L4; femoral neck | No | NA | No | NA | No | NA | Chronic back pain
Semler, 2008^71^ | NA | No | NA | Yes | Count | No | NA | Mobility (Brief Assessment of Motor Function); Tilting-angle to calculate ground reaction force and measure improvement in muscle force
Bemben, 2010^57^ | Total body; AP lumbar spine L1-L4; Dual proximal femur (femoral neck, trochanter, total hip); 33% radius of forearm | No | NA | No | NA | No | NA | Bone turnover markers from blood samples (C-terminal telopeptide of Type 1 collagen (CTX) for bone resorption and bone alkaline phosphatase (Bone ALP) for bone formation); Muscle Strength
Verschueren, 2004^32^ | Total hip; Total body; lumbar spine | No | NA | No | NA | No | NA | Bone turnover markers from blood samples (serum osteocalcin for bone formation and C-telopeptide level (CTX) for bone resorption); Muscle strength (isometric, dynamic); Fat mass and muscle mass; Postural control
von Stengel, 2010^27^ | Lumbar spine L1-L4; proximal femur | No | NA | No | NA | No | NA | Falls
Rubin, 2004^30^ | Proximal right and left femora: neck, trochanter; lumbar spine, distal one-third of nondominant radius | No | NA | No | NA | No | NA | Compliance; Efficacy of device use; Bone formation and resorption through serum and urine samples
Russo, 2003^52^ | Tibia: trabecular and cortical | No | NA | No | NA | No | NA | Muscle power
Iwamoto, 2005^31^ | Lumbar spine L1-L4 antero-posterior view | No | NA | Yes | X-ray | No | NA | Back pain; Urinary NTX, serum ALP, serum calcium, serum phosphorous); Falls
Gilsanz, 2006^47^ | Lumbar spine L1-L3; Total body | Yes | DXA | No | NA | No | NA | Muscle area
Pitukcheewanont, 2006^72^ | L1-L3 of lower axial spine (cancellous BD); Femurs (cortical BD) | No | NA | No | NA | No | NA | Fat mass; Femoral muscle mass; Bone area; Bone-specific alkaline phosphatase (BALP)
Ezenwa, 2008^73^ | Lumbar spine L1-L4; Total hip; Femoral neck; Trochanter; Forearm | No | NA | No | NA | No | NA | NA