# Example of Whole-Body Vibration Platform

Source: Journal of Bone and Mineral Research, 2004. Used with permission.30

Rubin C, Recker R, Cullen D, et al. Prevention of postmenopausal bone loss by a low-magnitude, high-frequency mechanical stimuli: a clinical trial assessing compliance, efficacy, and safety. Journal of Bone & Mineral Research. Mar. 2004;19(3):343-51. (Figure 1A). [pmid: 15040821].