# Published Literature Search Strategy

Preliminary literature search. We searched the MEDLINE, Cochrane Library, CINAHL, CSA Physical Education Index Web of Science, PEDro, and Academic Search Premier databases using the key words “whole body vibration,” “vibration,” and “osteoporosis.”

Software: Ovid Technologies, Inc. Email Service

----------------------

Search for: 18 not 19

Results: 120

Database: Ovid MEDLINE(R) <1950 to August Week 4 2010>

Search Strategy:

--------------------------------------------------------------------

1. exp Vibration/tu [Therapeutic Use] (511)
2. whole body.mp. (39402)
3. 1 and 2 (71)
4. exp Muscle Strength/ (10075)
5. exp "Recovery of Function"/ (19156)
6. 4 or 5 (28640)
7. 1 and 6 (27)
8. 3 or 7 (85)
9. wbv.mp. (309)
10. 1 and 9 (36)
11. 8 or 10 (85)
12. exp Muscle, Skeletal/ (165830)
13. 1 and 12 (65)
14. 11 or 13 (114)
15. exp Physical Therapy Modalities/ (99436)
16. 1 and 15 (206)
17. 14 or 16 (278)
18. limit 17 to (English language and humans and yr="2000 -Current") (127)
19. limit 18 to (case reports or editorial) (7)
20. 18 not 19 (120)
21. exp Osteoporosis/rh, th [Rehabilitation, Therapy] (2609)
22. 1 and 21 (14)

PubMed search strings | #
Search "Vibration/therapeutic use"[MAJR] Limits: Humans, Randomized Controlled Trial, English | 68
Search "Vibration/therapeutic use"[MAJR] Limits: Humans, Journal Article, English | 1287
Search "Vibration"[Mesh] Limits: Humans, Journal Article, English | 6541
Search vibration AND osteoporosis Limits: Humans, Journal Article, English | 71
Search vibration AND osteoporosis | 119
Cochrane Library: Whole body vibration for preventing and treating osteoporosis (Protocol)
CINAHL: 212 references