# Interview Guides for Key Informants

Questions for osteoporosis experts, whole-body vibration experts, and manufacturers
a. What are the criteria used to determine appropriate patient populations for whole-body vibration therapy?
b. What are the potential advantages and disadvantages of vibration therapy when compared to regular exercise and pharmacological treatments of osteoporosis in preventing osteoporotic fractures?
c. What modifications of vibration platforms are available in the U.S.? What modifications of vibration platforms are in development?
d. What is the current FDA-approval status of vibration therapy for adults with osteoporosis?
e. What kinds of training, certification, and staffing are required for vibration therapy?
f. What type of research is needed most? What research designs are most likely to answer the important research questions?
g. What outcomes are appropriate measures of the efficacy and effectiveness of vibration therapy?
h. When should patient outcomes be measured (length of followup)?

Questions for clinicians, patients, and patient advocates
a. What has been your experience with whole-body vibration therapy?
b. What information do clinicians and patients need to know to make informed decisions about whole-body vibration (effectiveness, safety, FDA approval, doctor recommendation, other)?
c. What information do clinicians and patients need to know when to use alternative therapeutic options for osteoporosis?
d. What is the measurement of successful treatment for osteopenia and osteoporosis?

Questions for third-party payers
a. What information about whole-body vibration is most needed by payers?
b. What criteria (clinical effectiveness, safety, FDA approval, market value, others) are the most critical when making payment coverage decisions for whole-body vibration?
c. What kinds of research would be most useful to make evidence-based coverage decisions?
d. What outcomes do payers take into consideration for coverage decisions?