# Definition of Terms

Bone mineral density: The amount of mineral (calcium phosphate) per square centimeter of bone. Bone mineral density values are calculated by using reference values for healthy young white women who are 20 to 29 years of age and are expressed in standard deviation (SD) units and reported as a T-score:75
  Normal bone density: | T-score ≥1 SD below young adult reference mean
  Osteopenia: | T-score between1 and 2.5 below young adult reference mean
  Osteoporosis: | T-score ≤2.5 SD below young adult reference mean
Whole-body vibration therapy: Whole-body vibration is the mechanical repetitive movement, or oscillatory motion, around an equilibrium point. Whole-body vibration therapy is a forced oscillation, where vibrations generated by motors underneath a vibration platform are transmitted to the person on the machine. Whole-body vibration platforms currently available produce sinusoidal shaped oscillations.
Whole-body vibration frequency: Repetition rate of the cycles of oscillation. The frequency of oscillations per second is denoted in hertz (Hz).
Whole-body vibration amplitude: Maximal displacement from equilibrium position. The amplitude is denoted in millimeters (mm).
Whole-body vibration peak-to-peak displacement: Displacement from the lowest to the highest point of the vibrating platform position. The peak-to-peak displacement is denoted in mm.
Whole-body vibration acceleration: Maximal rate of change in velocity during an oscillation cycle. It is a function of the frequency and peak-to-peak displacement (meters/second*second), and it is often expressed as multiples of Earth’s gravity (9.80665 meters/second*second) denoted by the symbol (g).