# Acknowledgments

We thank Karen Lohmann Siegel, P.T., M.A. for her contributions in formulating this technical brief.