# Methods

This Technical Brief has three key questions, as described in the Statement of Work. Key questions 1 and 2 are addressed using information from gray literature searches and narrative review articles. Key question 3 is addressed with a systematic scan of the published medical literature.

## Terminology, Definitions, and Conventions

### (Charged) Particle Beam Radiotherapy

This includes external radiotherapy that uses protons, helium, carbon, neon, silicon ions or other charged particles. External radiotherapy with electrons, neutrons or π-mesons is not discussed in this Technical Brief.

### Cancer

The operational definition of cancer includes histologically malignant tumors. All other entities or diseases are not considered as “cancer” in this Technical Brief. Examples of other conditions are arteriovenous malformations, benign meningiomas, benign schwannomas, craniopharyngioma, or age-related macular degeneration.

### (Absorbed) Radiation Dose

The amount of energy deposited in a given volume of tissue. It is measured in Gray (Gy).

### Relative Biological Effectiveness

RBE is the ratio of the dose of (typically) Co-60 photon radiation that will produce a specified biological effect, to the dose of charged particle radiation required to produce the same effect. Exact RBE values can differ across tissues or with particle energy and/or depth (in the patient’s body).

### Biologically Effective Dose

The biological effects of a given radiation dose depend on many factors, including type of radiation (photons vs. charged particles), energy of radiation and the composition of the tissue. The biologically effective dose is a concept that incorporates the aforementioned factors, and correlates better with biological effects compared to radiation dose. Generally speaking, it is related to the (absorbed) radiation dose by the following formula:

Biologically effective dose = RBE × radiation dose

and is measured in (typically Co-60) Gray equivalents, or GyE.

### End-of-Page Footnotes Vs. References

To distinguish Internet and gray literature sources from journal references we follow the convention of listing the former in the bottom of each page using lowercase latin numerals (^i, ii, iii, …^), and the latter in the References section in the end of the Technical Brief using arabic numerals (^1, 2, 3…^).

## Gray Literature Searches

We searched the Internet using the following algorithm. We first searched Google for “particle beam therapy” and “proton beam therapy”, and visited links we considered relevant among those in the first 10 pages of returned results. We visited links hosted in relevant websites or news items and identified the webpages of radiotherapy organizations, institutions that perform particle beam therapy around the world, and companies that develop particle beam therapy instrumentation and treatment planning software.

We also searched the FDA Center for Devices and Radiological Health (CDRH) database to identify particle beam therapy instrumentation that has received FDA clearance (we used the FDA product code “LHN” to identify relevant instrumentation). Finally, we queried the FDA Manufacturer and User Facility Device Experience (MAUDE) database for any reported harms with particle beam therapy instrumentation.

Selected websites and the corresponding links are provided in Appendix A. All listed links in this Technical Brief were active on 10/29/2008.

## Published Literature Searches

We performed Ovid MEDLINE searches from 1950 onwards (last search 02/12/2008) using terms such as “proton”, “charged particle”, “helium ion” etc., along with text and MeSH terms for cancer. The complete search strategy is described in Appendix B. We limited searches to human subjects, but we did not set any language or geographical restrictions. We did not use methodological filters to select specific study designs. We updated the aforementioned search to identify additional comparative studies on 07/11/2009. No additional comparative studies were found.

## Systematic Literature Scan

### Study Eligibility

Four reviewers screened citations at the abstract level to identify potentially relevant studies. All potentially eligible citations were retrieved in full text and were examined for eligibility. We included studies of any design describing particle beam radiotherapy in at least 10 patients with cancer, and reporting any clinical outcome (e.g., death, local tumor control, change in symptoms) or any harm (irrespective of whether it was attributed to particle beam radiotherapy or not). We included studies irrespective of the role of particle beam therapy in the patient management strategy (e.g., sole treatment or in combination with other treatments). We accepted studies published in English, German, French, Italian, and Japanese.

We excluded from the literature scan studies that compared different treatment plans/algorithms, as well as dosimetry-only studies (provided that they did not report any clinical outcomes or harms). We also excluded studies where more that 20% of patients had non-malignant conditions. Case series of less than 10 patients and case reports were not included in the literature scan, but were screened to identify potential harms.

### Data Abstraction

We used Epidata version 3.1 to abstract information on the items of interest in electronic forms.5 The initial version of the data abstraction form was piloted with 15 papers on 5 different types of cancer, and was modified in an iterative process.

We abstracted data on the citation, study design (prospective single arm study, retrospective single arm study, randomized controlled trial [RCT] and nonrandomized comparative study), type of cancer, patient eligibility criteria, study followup and the period over which patients were treated, as reported in the primary studies. For comparative studies we noted the exact comparisons.

We also recorded the center/facility of particle beam treatment and the number of patients who were treated. We noted the type of particle, total biologically effective dose (in GyE), number of fractions, biologically effective dose per fraction (GyE), and the duration of radiation treatment in weeks. For studies reporting treatment with both particle and photon beams, the aforementioned quantities were extracted in total for both radiotherapy modalities. When the dose per radiation fraction was not reported, it was calculated assuming that all fractions were of equal size. Similarly, whenever total treatment duration was not reported, it was calculated assuming administration of 1 radiation fraction per day, 5 days a week.

We noted information on particle generation and acceleration, beam transportation and the name of treatment planning software or systems (algorithms).

From each study, we gathered information on prior and concurrent treatments (photon radiotherapy, brachytherapy, surgical intervention, chemotherapy, hormonal therapy). We considered “concurrent” all treatments that were administered simultaneously or successively, as long as it could be judged that they were administered as part of a single intervention strategy. “Prior treatments” were the initial failed interventions in patients who were treated for relapse. In practice however, the distinction of prior and concurrent treatments was difficult.

For each study, we recorded whether the following outcomes where reported: overall or cause-specific survival, outcomes related to local tumor control (e.g., [no] local recurrence, complete remission, change in tumor size), outcomes related to distal disease control (metastasis, metastasis free survival), as well as any other clinical outcome, general (e.g., symptomatic relief) or disease-specific (e.g., rate of bladder conservation for bladder cancer).

We also recorded the different harms or adverse events, their timing (acute vs. late) and severity, as reported in the primary studies. Unless otherwise classified in the primary studies, we considered harms that were Grade 3 or higher as “severe”; and harms reported at least 3 months after irradiation as “late”. It should be noted that harms may be incurred by radiation therapy or other treatment interventions, such as chemotherapy or surgery. We recorded the study authors’ opinions on which harms were radiation-induced whenever they were reported; in all other cases we did not attempt to attribute specific harms to different interventions.

#### Note

It is not the intent of this Technical Brief to assess the outcomes of particle beam therapy for any specific condition.

The literature scan did not abstract numerical data on the rates of clinical outcomes or harms. Most studies were single-arm and comparisons across such studies are subject to confounding and can be misleading. Moreover, many studies refer to overlapping patient populations and are not independent.

### Synthesis of Items of Interest

We generated a Summary Table summarizing the 8 items of Key Question 3 (see Statement of Work, items 3.a. to 3.h.) per type of cancer; this is provided in Appendix G. We described the 8 items across all identified papers using graphs and tables, and providing qualitative summaries.

We classified papers according to the different cancer types they described in the following categories:

- Ocular cancer, including mostly uveal melanoma (but also metastasis to the retina and conjunctival cancer)
- Head and neck cancers, including malignancies of the brain (e.g., glioblastoma); of the skull base and of the cervical spine (chordomas and chondrosarcomas), along with other malignancies (e.g., of the sinonasal tract)
- Spinal cancer, including sacral tumors, mainly chordomas and chondrosarcomas
- Gastrointestinal cancers, including liver, esophageal, pancreatic, and bile duct tumors
- Prostate cancer
- Bladder cancer
- Uterine cancer, including uterine cervix and body
- Bone and soft tissue cancers
- Lung cancer (non-small cell)
- Breast cancer
- Miscellaneous (including skin cancer and papers describing a center’s experience with a variety of different cancers)

In addition, specific radiotherapy centers or institutes are no longer active, but were succeeded by another center in the same geographical area (and in the same academic environment). For example, the Harvard Cyclotron Laboratory has been succeeded by the Northeast Proton Therapy Center, and the Lawrence Berkeley Laboratory has been succeeded by the University of California San Francisco proton treatment center. In the presentation of literature scan results, we grouped papers originating from the currently inactive centers along with papers originating from the corresponding centers that succeeded them.

### Software

Epidata version 3.1 was used to perform data extraction from eligible papers.5 Stata/SE version 9 (Stata Corp, College Station, TX) was used for descriptive statistics and graphics.