# Discussion

Most common radiotherapy modalities use photon irradiation in the locoregional treatment of cancer. Instead, particle beam radiotherapy uses beams of protons or other charged particles such as helium, carbon or other ions. Charged particles have different depth-dose distributions compared to photons. Their physical properties allow precise targeting of the Bragg peak (and therefore the radiation dose) anywhere inside the patient’s body. The charged particle beam can be conformed to cover tumors of different shapes.

Few centers worldwide have the large and very expensive facilities to provide this treatment. Technological advances made possible the construction of smaller proton beam treatment instrumentation, and already several hospitals in the US have expressed interest to obtain it.

We relied heavily on gray literature (Internet) searches to obtain information on the number of particle beam facilities around the world, their location, instrumentation and whether they are currently active or not. The same was true for information on emerging technologies. We explored the web in a semistructured way to record information from institutional websites, and websites from organizations and companies constructing particle beam treatment facilities. However, we cannot be confident that we have obtained all existing important information, and we cannot verify the validity of the retrieved information from the various websites. Web searching was a necessary component of the methodology of the Technical Brief; relying on review articles (and published literature in general) would provide only limited or out of date information. Better methods for systematic Internet searches on new technologies have to be developed (and validated to the extent possible).

The Technical Brief focused only on studies with primary data in humans, and did not consider the large body of literature on dosimetric and simulation studies. The available slots for particle beam radiotherapy are very limited, and this may have impacted the design of studies conducted to date. The majority of studies included in the Technical Brief are noncomparative and relatively small in size. Most are retrospective and report a center’s experience in treating patients with a given cancer, so that some publications from the same centers likely refer to overlapping populations. Studies report results over long followup periods (in excess of 12 months); however it is not clear whether few people are generally lost to followup or whether people without a minimum followup duration were routinely excluded. Reported outcomes included survival (overall and cause specific) and outcomes pertaining to local and distal disease control.

Only a handful of RCTs and nonrandomized comparative studies were identified, and they compared lower vs. higher doses of particle beam therapy, particle beam therapy alone vs. other treatment, or incorporation of particle beam therapy to a treatment strategy vs. not. Studies comparing strategies that include particle beam therapy against contemporary alternatives are most informative. From that point of view, comparisons between different types of charged particle therapies should not be the only comparisons that are being evaluated (at least in most types of cancers).

In general, RCTs are needed to reliably assess the comparative efficacy (and sometimes safety) of interventions, as long as there is clinical equipoise (genuine uncertainty) over the preferred one.59 For certain cancers (and specific outcomes) the choice between particle beam radiotherapy and other alternatives is easy to make. For example, in patients with uveal melanomas, particle beam radiotherapy will result in higher eye retention rates compared to surgery (which typically involves enucleation of the eye). However, for many common cancers and for many clinical outcomes there is genuine clinical equipoise. Furthermore, pathophysiological rationale, however strong, is not sufficient to choose the optimal treatment. There are numerous examples of interventions that, despite very favorable and strong pathophysiological rationale, turned out to be harmful when evaluated in RCTs.

It has been argued that for the comparison between e.g., proton and conventional radiotherapy there is no real equipoise (protons are better):60 First, the dose distributions that can be achieved with protons are in almost all cases superior to those possible with x-rays.60,61 Second, the biological effects of protons are very similar to those of photons, so the only possible differences stem from their physical properties. Third, radiation harms normal tissues as it harms malignant ones, and sparing normal tissues from radiation is self-evidently beneficial. For these reasons, there is “[verbatim] a high probability that protons can provide superior therapy to that possible with x-rays in almost all circumstances,”60 and “[verbatim] practitioners of proton beam therapy have found it ethically unacceptable to conduct RCTs comparing protons with x-rays.”60

The aforementioned line of reasoning is unsubstantiated, because it indiscriminately equates increased precision in delivering the planned radiation treatment with positive patient-relevant outcomes. This is evidently not the case when broad radiotherapy fields are indicated (e.g., whole brain radiotherapy, whole pelvis radiotherapy) to treat disease that may be locally advanced: the high precision of charged particle therapy is neither necessary nor desirable. Using a similar rationale, it is simply unknown whether precise radiation targeting can sometimes result in worse local disease control compared to conventional radiotherapy for some common cancers. Imaging limitations can underestimate the true extent of the disease and therefore mislead treatment planning; by its very nature, charged particle radiotherapy has less tolerance for inadequacies in treatment planning. (For example, there may be satellite lesions that are just distal to the fall-off of an incorrectly planned Bragg peak.) Finally, even the theorized reductions in the rate and severity of harms with particle beam therapy rather than conventional therapies have not yet been convincingly demonstrated in well-designed comparative studies.

It is not easy to decide for which cancers RCTs are necessary (and if so, for what comparisons e.g., proton radiotherapy vs. conventional radiotherapy, IMRT, or stereotactic radiosurgery). The theorized incremental clinical benefit with charged particle therapy vs. a specific type of photon based radiotherapy will vary across cancers, ranging from maximal to negligible (or even harm), and should be considered together with the corresponding incremental costs (and risks). Especially for common cancers, it is not clear where exactly along the continuum it becomes “unethical” to randomize patients.

Notwithstanding the need for RCTs, there are additional approaches that can provide potentially useful insights. Nonrandomized prospective comparative studies using proper statistical analyses that are superior to simple adjustments (such as propensity score-based analyses62 or instrumental variable regression analyses63) can be used to explore the comparative effectiveness and especially safety of charged particle therapy vs. conventional radiotherapy. Although nonrandomized designs cannot provide definitive evidence, their results may challenge conventional wisdom and formulate hypotheses for testing in randomized studies.

We clarify that there is still need for research on clinical and technical issues pertinent to particle beam therapy. Treatment protocols for charged particle therapy are constantly being refined, and the underlying complexities and considerations can differ drastically with particle type, treatment planning methodologies, cancer type and patient comorbidities. In addition, ongoing rapid technological advances in medical imaging, treatment planning and radiotherapy delivery methodologies mandate further studies to optimize charged particle radiotherapy protocols. However, to justify any widespread use of charged particle radiotherapy to common cancers and to better appreciate the expected benefits, risks and costs it is necessary to have more comparative studies in general, and randomized trials in particular.

With newer technological advances, particle beam therapies are expected to become increasingly available (and, perhaps, at reduced cost). They will likely be used to treat patients with broader indications. This anticipated diffusion of the technology can have important implications (on economic aspects, prioritization of resources, or even on health outcomes). Especially for many patients with common cancers, such as breast, prostate, lung, and pancreatic cancers, where extreme precision in dose targeting is not a sine-qua-non, it is essential that the theorized advantages of particle beam therapy vs. contemporary alternative interventions are first proven in controlled clinical trials. Concomitant economic evaluations would probably prove useful in informing cost-effectiveness or other economic analyses.

It is likely that focused systematic reviews will not be able to provide a definitive answer on the effectiveness and safety of charged particle beam radiotherapies compared to alternative interventions. This is largely because of the relative lack of comparative studies in general, and randomized trials in particular. For example, a recent Effective Health Care (EHC) report64 that included a systematic review65 on the comparative effectiveness and harms of treatments for clinically localized prostate cancer did not provide a definitive conclusion on the role of proton beam radiotherapy.

## Conclusion

In brief, there are many publications on particle (mainly proton) beam therapy for the treatment of cancer. However, they typically do not use a concurrent control, focus on heterogeneous populations, and employ different definitions for outcomes and harms. Comparative studies in general, and randomized trials in particular, are likely needed to document the theorized incremental advantages of particle beam therapy over other radiotherapies (e.g., IMRT, conventional radiotherapy or stereotactic photon radiosurgery) in many cancers. In addition, incremental benefits should be considered and interpreted with respect to corresponding incremental costs (and risks). This is especially important in the light of the anticipated diffusion of this technology to treating common cancers in which extreme precision in radiation delivery is not a sine-qua-non. We anticipate that systematic reviews of the current literature will not be able to provide definitive answers on the effectiveness and safety of particle beam therapy compared to other interventions for most if not all cancer categories.