# Appendixes

Appendix A Selected Internet Links

Appendix B Ovid Medline Search Strategy

Appendix C Table of Eligible Studies

Appendix D Table of Excluded Studies

Appendix E Table of Screened Case Series and Case Reports

Appendix F Centers That Perform Particle Beam Treatment (Worldwide)

Appendix G Summary Table