# Centers That Perform Particle Beam Treatment (Worldwide)

Appendix Table F1 Operating particle beam facilities around the world

Institute | Country | Particle | Maximum Clinical Energy (MeV) | Beam direction | | | First patient | N treated | Date of N treated
Institute | Country | Particle | Maximum Clinical Energy (MeV) | H | V | Gan | First patient | N treated | Date of N treated
ITEP, Moscow | Russia | proton | 250 | Y | – | – | 1969 | 4024 | Dec-07
St.Petersburg | Russia | proton | 1000 | Y | – | – | 1975 | 1327 | Dec-07
PSI, Villigen | Switzerland | proton | 72 | Y | – | – | 1984 | 4875 | Dec-07
Dubna | Russia | proton | 200^***^ | Y | – | – | 1999 | 402 | Dec-07
Uppsala | Sweden | proton | 200 | Y | – | – | 1989 | 840 | Dec-07
Clatterbridge | England | proton | 62 | Y | – | – | 1989 | 1701 | Dec-07
Loma Linda | USA | proton | 250 | Y | – | Y | 1990 | 11414 | Nov-06
MPRI(2) | USA | proton | 200 | Y | – | – | 1993 | 379 | Dec-07
UCSF | USA | proton | 60 | Y | – | – | 1994 | 920 | Mar-07
Nice | France | proton | 65 | Y | – | – | 1991 | 3129 | Sep-06
Orsay | France | proton | 200 | Y | – | – | 1991 | 4143 | Dec-07
iThemba Labs | South Africa | proton | 200 | Y | – | – | 1993 | 500 | Dec-07
HIMAC, Chiba | Japan | ion | 800/u | Y | Y | – | 1994 | 3795 | Jan-08
TRIUMF, Vancouver | Canada | proton | 72 | Y | – | – | 1995 | 130 | Dec-07
PSI, Villigen | Switzerland | proton ** | 250^*^ | – | – | Y | 1996 | 320 | Dec-07
G.S.I. Darmstadt | Germany | ion^**^ | 430/u | Y | – | – | 1997 | 384 | Dec-07
HMI, Berlin | Germany | proton | 72 | Y | – | – | 1998 | 1014 | Dec-07
NCC, Kashiwa | Japan | proton | 235 | – | – | Y | 1998 | 552 | Dec-07
HIBMC, Hyogo | Japan | proton | 230 | – | – | Y | 2001 | 1658 | Dec-07
HIBMC, Hyogo | Japan | ion | 320 | Y | Y | – | 2002 | 271 | Dec-07
PMRC(2), Tsukuba | Japan | proton | 250 | – | – | Y | 2001 | 1188 | Dec-07
NPTC, MGH Boston | USA | proton | 235 | Y | – | Y | 2001 | 2710 | Oct-07
INFN-LNS, Catania | Italy | proton | 60 | Y | – | – | 2002 | 151 | Dec-07
Shizuoka | Japan | proton | 235 | Y | – | Y | 2003 | 570 | Dec-07
Wakasa WERC, Tsuruga | Japan | proton | 200 | Y | Y | – | 2002 | 49 | Dec-07
WPTC, Zibo | China | proton | 230 | Y | – | Y | 2004 | 537 | Dec-07
MD Anderson Cancer Center, Houston, TX | USA | proton | 250 | Y | – | Y | 2006 | 527 | Dec-07
FPTI, Jacksonville, FL | USA | proton | 230 | Y | – | Y | 2006 | 360 | Dec-07
NCC, IIsan | South Korea | proton | 230 | Y | – | Y | 2007 | 155 | Dec-07

N: number; H: horizontal; V: vertical; Gan: Gantry

* degraded beam for 1996 to 2006; dedicated 250 MeV proton beam from 2007 onwards

** with beam scanning (all others with spread beam)

*** degraded beam

Ordered by the time of treatment of the first patient.

Source: Particle Therapy Cooperative Group, available at http://ptcog.web.psi.ch/. Accessed June 16, 2008.

Appendix Table F2 Particle beam facilities that are being planned around the world

Institute | Country | In construction | Particle | Maximum Clinical Energy (MeV) [Accelerator] | Treatment rooms | Gantries | Start date
RPTC, Munich | Germany | Y | proton | 250 [SCC] | 5 | 4 | 2008
WPE, Essen | Germany | Y | proton | 230 [Cyc] | 4 | 3 | 2009
Heidelberg/GSI Darmstadt | Germany | Y | proton, ion | 430 [SCC] | 3 | 1 | 2008
PTC, Marburg | Germany | Y | proton, ion | 430 [Syn] | 4 | 0 | 2010
Kiel | Germany | N | proton, ion | 430 [Syn] | 3 | 0 | 2012
RPTC, Koeln | Germany | N | proton | 250 [SCC] | 5 | 4 | ?
PSI, Villigen | Switzerland | Y | proton | 250 [SCC] | 3 | +1 | 2007/08
UPenn | USA | Y | proton | 230 [Cyc] | 5 | 4 | 2009
Northern Illinois PT Res.Institute, W. Chicago, IL | USA | N | proton | 250 | 4 | 2 | 2010
Med-AUSTRON | Austria | N | proton, ion | ? [Syn] | 3 to 4 (?) | 2 | ?
Trento | Italy | N | proton | 230 [Cyc] | 2 | 1 | 2010?
CNAO, Pavia | Italy | Y | proton, ion | 430 [SCC] | 3 to 4 | 1 | 2009?
iThemba Labs | South Africa | N | proton | 230 [SCC] | 3 | 1 | ?
CPO, Orsay | France | Y | proton | 230 [Cyc] | 3 | 1 | 2010

Cyc: Cyclotron; N: no; SCC: Synchrocyclotron; Syn: synchrotron; Y: yes

Source: Particle Therapy Cooperative Group, available at http://ptcog.web.psi.ch/. Accessed June 16, 2008.

Also, Tufts Medical Center (Boston, MA, USA) announced plans to start building a particle beam facility.