# Table of Screened Case Series and Case Reports

Citation | PMID
Bacchetti S, Bressan P, Della MG. Melanoma of the choroid above the optic disc: considerations concerning a clinical case. Ophthalmologica 1998;212(Suppl 1):53–6. | 9730752
Bhattacharyya N, Thornton AF, Joseph MP, et al. Successful treatment of esthesioneuroblastoma and neuroendocrine carcinoma with combined chemotherapy and proton radiation. Results in 9 cases. Archives of Otolaryngology—Head & Neck Surgery 1997;123(1):34–40. | 9006501
Char DH, Castro JR, Quivey JM, et al. Helium ion charged particle therapy for choroidal melanoma. Ophthalmology 1980;87(6):565–70. | 7413146
Char DH, Crawford JB, Castro JR, et al. Failure of choroidal melanoma to respond to helium ion therapy. Archives of Ophthalmology 1983;101(2):236–41. | 6824468
Chazalon-Pauleau E, Roux L, Patte JH, et al. [Conjunctival melanoma at corneoscleral limbus on primary acquired melanosis. A case report] [French]. Journal Francais d Opthalmologie 2007;30(8):e22. | 17978670
Colli BO, Al-Mefty O. Chordomas of the skull base: follow-up review and prognostic factors. Neurosurgical Focus 2001;10(3):E1. | 16734401
Coppeto JR, Roberts M. Fibrosarcoma after proton-beam pituitary ablation. Archives of Neurology 1979;36(6):380–1. | 454238
Croughs P, Deman C, Richard F, et al. Treatment of retinoblastoma using accelerated protons] [French]. Bulletin de la Societe Belge d Ophtalmologie 1992;243:81–5. | 1338776
Currier BL, Papagelopoulos PJ, Krauss WE, et al. Total en bloc spondylectomy of C5 vertebra for chordoma. Spine 2007;32(9):E294–9. | 17450062
D’Hermies F, Meyer A, Morel X, et al. [Neovascular glaucoma following proton-beam therapy. Case report] [French]. Journal Francais d Opthalmologie 2001;24(1):95–101. | 11240479
DeVries A, Munzenrider JE, Hedley-Whyte T, et al. [The role of radiotherapy in the treatment of malignant meningiomas] [German]. Strahlentherapie und Onkologie 1999;175(2):62–7. | 10065140
Dithmar S, Diaz CE, Grossniklaus HE. Intraocular melanoma spread to regional lymph nodes: report of two cases. Retina 1920:76–79. | 10696752
Dziuk E, Merta A, Bocian E. Accidental irradiation of skin on hands with a proton beam of 4 MeV energy. Strahlentherapie 1973;146(6):685–92. | 4792265
Fries PD, Char DH, Crawford JB, et al. Sympathetic ophthalmia complicating helium ion irradiation of a choroidal melanoma. Archives of Ophthalmology 1987;105(11):1561–4. | 3675290
Fukumitsu N, Tokuuye K, Sugahara S, et al. A patient surviving for eight years after proton and x-ray irradiation for advanced esophageal cancer. Acta Oncologica 2006;45(8):1132–4. | 17118851
Gear HC, Kemp EG, Kacperek A, et al. Treatment of recurrent orbital haemangiopericytoma with surgery and proton beam therapy. British Journal of Ophthalmology 2005;89(1):123–4. | 15615763
Gerber DS, Campo RV. Acute and chronic keratitis with ulceration after corneal exposure to helium ion irradiation. American Journal of Ophthalmology 1987;104(2):189–90. | 3618720
Gohongi T, Tokuuye K, Iida H, et al. Concurrent proton beam radiotherapy and systemic chemotherapy for the metastatic liver tumor of gastric carcinoma: a case report. Japanese Journal of Clinical Oncology 2005;35(1):40–4. | 15681604
Goodman DF, Char DH, Crawford JB, et al. Uveal melanoma necrosis after helium ion therapy. American Journal of Ophthalmology 1986;101(6):643–5. | 3717245
Gradoudas ES, Goitein M, Koehler A, et al. Proton irradiation of choroidal melanomas. Preliminary results. Archives of Ophthalmology 1978;96(9):1583–91. | 99132
Graffman S, Haymaker W, Hugosson R, et al. High-energy protons in the postoperative treatment of malignant glioma. Acta Radiologica: Therapy, Physics, Biology 1975;14(5):443–61. | 173141
Gragoudas ES, Goitein M, Koehler AM, et al. Proton irradiation of small choroidal malignant melanomas. American Journal of Ophthalmology 1977;83(5):665–73. | 405869
Gragoudas ES, Carroll JM. Multiple choroidal metastasis from bronchial carcinoid treated with photocoagulation and proton beam irradiation. American Journal of Ophthalmology 1979;87(3):299–304. | 219697
Gragoudas ES, Goitein M, Verhey L, et al. Proton beam irradiation. An alternative to enucleation for intraocular melanomas. Ophthalmology 1980;87(6):571–81. | 6251410
Grizzard WS, Torczynski E, Char DH. Helium ion charged-particle therapy for choroidal melanoma. Histopathologic findings in a successfully treated case. Archives of Ophthalmology 1984;102(4):576–8. | 6704015
Habrand IL, ustin-Seymour M, Birnbaum S, et al. Neurovisual outcome following proton radiation therapy. International Journal of Radiation Oncology, Biology, Physics 1989;16(6):1601–6. | 2542198
Habrand JL, Mammar H, Ferrand R, et al. Proton beam therapy (PT) in the management of CNS tumors in childhood. Strahlentherapie und Onkologie 1999;175(Suppl 2):91–4. | 10394410
Haimovici R, Mukai S, Schachat AP, et al. Rhegmatogenous retinal detachment in eyes with uveal melanoma. Retina 1996;16(6):488–96. | 9002131
Hata M, Tokuuye K, Sugahara S, et al. Proton irradiation in a single fraction for hepatocellular carcinoma patients with uncontrollable ascites. Technical considerations and results. Strahlentherapie und Onkologie 2007;183(8):411–6. | 17680219
Hwang JM, Fu KK, Phillips TL. Results and prognostic factors in the retreatment of locally recurrent nasopharyngeal carcinoma. International Journal of Radiation Oncology, Biology, Physics 1998;41(5):1099–111. | 9719121
Igaki H, Tokuuye K, Takeda T, et al. Sequential evaluation of hepatic functional reserve by 99mTechnetium-galactosyl human serum albumin scintigraphy after proton beam therapy: a report of three cases and a review of the literatures [review] [27 refs]. Acta Oncologica 2006;45(8):1102–7. | 17118846
Kaufman M, Swartz BE, Mandelkern M, et al. Diagnosis of delayed cerebral radiation necrosis following proton beam therapy. Archives of Neurology 1990;47(4):474–6. | 2157383
Kincaid MC, Folberg R, Torczynski E, et al. Complications after proton beam therapy for uveal malignant melanoma. A clinical and histopathologic study of five cases. Ophthalmology 1988;95(7):982–91. | 2845323
Kirsch DG, Ebb DH, Hernandez AH, et al. Proton radiotherapy for Hodgkin’s disease in the sacrum. Lancet Oncology 2005;6(7):532–3. | 15992703
Koyama S, Kawanishi N, Fukutomi H, et al. Advanced carcinoma of the stomach treated with definitive proton therapy. American Journal of Gastroenterology 1990;85(4):443–7. | 2158230
Liszauer AD, Brownstein S, Corriveau C, et al. A clinicopathological study of seven globes enucleated after primary radiation therapy for malignant melanoma of the choroid or ciliary body. Canadian Journal of Ophthalmology 1990;25(7):340–4. | 2090338
Lovely TJ, Buchheit WA. Syringomyelia as a postoperative sequela of the resection of a chordoma of the clivus: case report. Neurosurgery 1991;28(3):431–3. | 2011227
Margo CE, Pautler SE. Granulomatous uveitis after treatment of a choroidal melanoma with proton-beam irradiation. Retina 1990;10(2):140–3. | 2402555
Mataftsi A, Zografos L, Chamot L, et al. [Choroidal melanoma in neurofibromatosis type 2: description of a case] [French]. Journal Francais d Opthalmologie 2003;26(5):477–80. | 12819605
Matsushita K, Ochiai T, Shimada H, et al. The effects of carbon ion irradiation revealed by excised perforated intestines as a late morbidity for uterine cancer treatment. Surgery Today 2006;36(8):692–700. | 16865512
Mayahara H, Oda Y, Kawaguchi A, et al. A case of hepatocellular carcinoma initially treated by carbon ions, followed by protons for marginal recurrence with portal thrombus. Radiation Medicine 2005;23(7):513–9. | 16485544
Minning Jr CA, Davidorf FH, Makley Jr TA, et al. Metastatic carcinoid to the choroid. Retina 1982;2(4):223–30. | 6101129
Morgan CM, Gragoudas ES. Limited choroidal hemorrhage mistaken for a choroidal melanoma. Ophthalmology 1987;94(1):41–6. | 3550566
Murakami M, Kagawa K, Hishikawa Y, et al. [Report on proton therapy according to good clinical practice at Hyogo Ion Beam Medical Center] [Japanese]. Nippon Igaku Hoshasen Gakkai Zasshi - Nippon Acta Radiologica 2002;62(2):79–85. | 11905036
Noel G, Habrand JL, Mammar H, et al. Highly conformal therapy using proton component in the management of meningiomas. Preliminary experience of the Centre de Protontherapie d’Orsay. Strahlentherapie und Onkologie 2002;178(9):480–5. | 12426833
Okumura T, Itai Y, Tsuji H, et al. Focused radiation hepatitis after Bragg-peak proton therapy for hepatocellular carcinoma: CT findings. Journal of Computer Assisted Tomography 1994 Oct;18(5):821–3. | 8089336
Otsuka M, Ohara K, Takada Y, et al. Radiation therapy for intrahepatic recurrence after hepatectomy for hepatocellular carcinoma. International Journal of Clinical Oncology 2003;8(3):151–5. | 12851838
Ronson B, Rossi C, Johnson S, et al. Locoregional proton radiotherapy of a primary cavernous sinus non-Hodgkin’s lymphoma: case report. Technology in Cancer Research & Treatment 2006;5(3):281–4. | 16700624
Shibuya S, Takase Y, Aoyagi H, et al. Definitive proton beam radiation therapy for inoperable gastric cancer: a report of two cases. Radiation Medicine 1991 Feb;9(1):35–40. | 1649484
Solares CA, Fakhri S, Batra PS, et al. Transnasal endoscopic resection of lesions of the clivus: a preliminary report. Laryngoscope 2005;115 (11):1917–22. | 16319599
Sudhamshu KC, Kouzu T, Matsutani S, et al. Primary malignant melanoma of the esophagus treated with heavy-ion radiotherapy. Journal of Clinical Gastroenterology 2003;37(2):151–4. | 12869887
Suit HD, Goitein M, Tepper JE, et al. Clinical experience and expectation with protons and heavy ions. International Journal of Radiation Oncology, Biology, Physics 1977;3:115–25. | 96045
Takagi K, Takada T, Amano H, et al. Late hemorrhage after pancreatoduodenectomy and heavy ion beam therapy. Journal of Hepato -Biliary -Pancreatic Surgery 2007;14(3):331–5. | 17520213
Timmermann B, Schuck A, Niggli F, et al. [Spot-scanning proton therapy for rhabdomyosarcomas of early childhood. First experiences at PSI] [German]. Strahlentherapie und Onkologie 2006;182(11):653–9. | 17072523
Torubarov FS, Zvereva ZF, Prikhod’ko AE. [A case of brain damage cause by high-energy proton flow] [Russian]. Zhurnal Nevrologii i Psikhiatrii Imeni S S Korsakova 2002;102(4):45–8. | 12001667
Torubarov FS, Zvereva ZF, Prikhod’ko AE. A case of brain damage due to a high-energy proton beam. Neuroscience & Behavioral Physiology 2003;33(3):227–30. | 12769053
Umebayashi Y, Uyeno K, Tsujii H, et al. Proton radiotherapy for malignant melanoma of the skin. Dermatology 190:210–213. | 7599383
Weber DC, Rutz HP, Lomax AJ, et al. First spinal axis segment irradiation with spot-scanning proton beam delivered in the treatment of a lumbar primitive neuroectodermal tumour. Case report and review of the literature [see comment] [review] [29 refs]. Clinical Oncology (Royal College of Radiologists) 2004;16(5):326–31. | 15341435
Yoshii Y, Tsunoda T, Hyodo A, et al. Proton radiation therapy for clivus chordoma—case report. Neurologia Medico-Chirurgica 1993;33(3):173–6. | 7683125
Young LH, Gragoudas ES. Macular uveal melanoma treated with proton beam irradiation. 10-year follow-up observation with histopathologic correlation. Retina 1994;14(1):43–6. | 8016461
Yuh GE, Loredo LN, Yonemoto LT, et al. Reducing toxicity from craniospinal irradiation: using proton beams to treat medulloblastoma in young children. Cancer Journal 2004 Dec;10(6):386–90. | 15701271
Zehetmayer M, Menapace R. Choroidal melanomas near the optic disk or macula. Long-term results after proton beam irradiation: a report of 3 cases. Ophthalmologica 206:18–23. | 8278155
Zinn KM, Pokorny K, Jakobiec FA, et al. Proton-beam irradiated epithelioid cell melanoma of the ciliary body. Ophthalmology 1981;88(12):1315–21. | 6275325
Mu X, Bjork-Eriksson T, Nill S, et al. Does electron and proton therapy reduce the risk of radiation induced cancer after spinal irradiation for childhood medulloblastoma? A comparative treatment planning study. Acta Oncologica 2005;44(6):554–62. | 16165914
Westekemper H, Anastassiou G, Sauerwein W, et al. [Analysis of ocular surface alterations following proton beam radiation in eyes with conjunctival malignant melanoma] [German]. Ophthalmologe 2006;103(7):588–95. | 16721565
Shah SK, Lui PD, Baldwin DD, et al. Urothelial carcinoma after external beam radiation therapy for prostate cancer. Journal of Urology 2006;175(6):2063–6. | 16697804
Massengale JL, Levy RP, Marcellus M, et al. Outcomes of surgery for resection of regions of symptomatic radiation injury after stereotactic radiosurgery for arteriovenous malformations. Neurosurgery 2006;59(3):553–60;discussion 553–60. | 16955037
Tsuji M, Kimura K, Tsuji H, et al. Histological study of choroidal malignant melanoma treated by carbon ion radiotherapy. Japanese Journal of Ophthalmology 2007 Apr;51(2):127–30. | 17401623
Smith V, Verhey L, Serago CF. Comparison of radiosurgery treatment modalities based on complication and control probabilities. International Journal of Radiation Oncology, Biology, Physics 1998;40(2):507–13. | 9457841
Di GS, Ottaviani F, Floris R, et al. Indium111 pentetreotide single photon emission computed tomography (In111 pentetreotide SPECT): a new technique to evaluate somatostatin receptors in chordomas. Journal of Laryngology & Otology 2005;119(5):405–8. | 15949110
Zhang X, Dong L, Lee AK, et al. Effect of anatomic motion on proton therapy dose distributions in prostate cancer treatment. International Journal of Radiation Oncology, Biology, Physics 2007;67(2):620–9. | 17236979
Tuckwell W, Bezak E. Calculation of the positron distribution from 15O nuclei formed in nuclear reactions in human tissue during proton therapy. Physics in Medicine & Biology 2007;52(9):2483–98. | 17440247
Parodi K, Paganetti H, Shih HA, et al. Patient study of in vivo verification of beam delivery and range, using positron emission tomography and computed tomography imaging after proton therapy. International Journal of Radiation Oncology, Biology, Physics 2007;68(3):920–34. | 17544003
Ahmadi T, Okumura T, Onaya H, et al. Preservation of hypervascularity in hepatocellular carcinoma after effective proton-beam radiotherapy—CT observation. Clinical Radiology 1999;54(4):253–6. | 10210346
Frank G, Sciarretta V, Calbucci F, et al. The endoscopic transnasal transsphenoidal approach for the treatment of cranial base chordomas and chondrosarcomas. Neurosurgery 2006;59(1 Suppl 1):ONS50-7;discussion ONS50-7. | 16888551
Marnitz S, Cordini D, Bendl R, et al. Proton therapy of uveal melanomas: intercomparison of MRI-based and conventional treatment planning. Strahlentherapie und Onkologie 2006;182(7):395–9. | 16826358
Hug EB, Adams J, Fitzek M, et al. Fractionated, three-dimensional, planning-assisted proton- radiation therapy for orbital rhabdomyosarcoma: a novel technique. International Journal of Radiation Oncology, Biology, Physics 2000;47(4):979–84. | 10863068
Ciulla TA, Bains RA, Jakobiec FA, et al. Uveal lymphoid neoplasia: a clinical-pathologic correlation and review of the early form. Survey of Ophthalmology 1997 Jun;41(6):467–76. | 9220569
Fischman AJ, Thornton AF, Frosch MP, et al. FDG hypermetabolism associated with inflammatory necrotic changes following radiation of meningioma. Journal of Nuclear Medicine 1997;38(7):1027–9. | 9225785
Hug EB, Nevinny-Stickel M, Fuss M, et al. Conformal proton radiation treatment for retroperitoneal neuroblastoma: introduction of a novel technique. Medical & Pediatric Oncology 2001;37(1):36–41. | 11466721
Austin-Seymour M, Griffin T, Laramore G, et al. High-LET radiation therapy of non-small cell lung cancer [review] [4 refs]. Chest 1989;96(1 Suppl):72S–73S. | 2544370
St Clair WH, Adams JA, Bues M, et al. Advantage of protons compared to conventional X-ray or IMRT in the treatment of a pediatric patient with medulloblastoma. International Journal of Radiation Oncology, Biology, Physics 2004;58(3):727–34. | 14967427
Schulz-Ertner D, Didinger B, Nikoghosyan A, et al. Optimization of radiation therapy for locally advanced adenoid cystic carcinomas with infiltration of the skull base using photon intensity-modulated radiation therapy (IMRT) and a carbon ion boost. Strahlentherapie und Onkologie 2003;179(5):345–51. | 12740662
Bowyer J, Natha S, Marsh I, Foy P. Visual complications of proton beam therapy for clival chordoma. Eye 17(3):318–23, 2003 | 12724692
Miralbell R, Lomax A, Cella L, et al. Potential reduction of the incidence of radiation-induced second cancers by using proton beams in the treatment of pediatric tumors. International Journal of Radiation Oncology, Biology, Physics 2002;54(3):824–9. | 12377335
McDermott AL, Dutt SN, Chavda SV, et al. Maffucci’s syndrome: clinical and radiological features of a rare condition [review] [18 refs]. Journal of Laryngology & Otology 2001;115(10):845–7. | 11668006
Sou R, Oku N, Ohguro N, et al. The clinical role of N-isopropyl-p-[123I]-iodoamphetamine single photon emission computed tomography in the follow-up of choroidal melanoma after radiotherapy. Japanese Journal of Ophthalmology 2004 Feb;48(1):54–8. | 14767652
Aoka Y, Kamada T, Kawana M, et al. Primary cardiac angiosarcoma treated with carbon-ion radiotherapy. Lancet Oncology 2004;5(10):636–8. | 15465468
Johansson J, Blomquist E, Montelius A, et al. Potential outcomes of modalities and techniques in radiotherapy for patients with hypopharyngeal carcinoma. Radiotherapy & Oncology 2004;72(2):129–38. | 15297132
Kozak KR, Kachnic LA, Adams J, et al. Dosimetric feasibility of hypofractionated proton radiotherapy for neoadjuvant pancreatic cancer treatment. International Journal of Radiation Oncology, Biology, Physics 2007;68(5):1557–66. | 17544599
Meyer A, D’Hermies F, Korobelnik JF, et al. [Ring recurrence of ciliary body melanoma after proton-beam therapy] [French]. Journal Francais d Opthalmologie 1920:697–700 | 9587582
Quetin P, Meyer L, Schumacher C, et al. [Conservative treatment of choroidal melanoma using iodine-125 brachytherapy, technique and preliminary analysis of 78 patients] [French]. Cancer Radiotherapie 2001;5(6):737–42. | 11797294
Nguyen QD, Foster CS. Ciliary body melanoma masquerading as chronic uveitis. Ocular Immunology & Inflammation 1998;6(4):253–6. | 9924921
Rich TA, Schiller A, Suit HD, et al. Clinical and pathologic review of 48 cases of chordoma. Cancer 1985;56(1):182–7. | 2408725
Yamamoto N, Miyamoto T, Nishimura H, et al. Preoperative carbon ion radiotherapy for non-small cell lung cancer with chest wall invasion—pathological findings concerning tumor response and radiation induced lung injury in the resected organs. Lung Cancer 2003;42(1):87–95. | 14512192
Rumen F, Labetoulle M, Lautier-Frau M, et al. [Sturge-Weber syndrome: medical management of choroidal hemangiomas] [French]. Journal Francais d Opthalmologie 2002;25(4):399–403. | 12011745
Liem SE, Armbruster FC. Proton-beam irradiation of subfoveal choroidal neovascular membranes in presumed ocular histoplasmosis syndrome: a case report. Journal of the American Optometric Association 1998;69(8):493–9. | 9747044
Kaphan E, Eusebio A, Witjas T, et al. [Primary leiomyosarcoma of the cavernous sinus associated with Epstein-Barr virus in a kidney graft] [review] [20 refs] [French]. Revue Neurologique 2003;159(11):1055–9. | 14710028
Kafkala C, Daoud YJ, Paredes I, et al. Masquerade scleritis. Ocular Immunology & Inflammation 2005;13(6):479–82. | 16321896
Disabato JA, Handler MH, Strain JD, et al. Successful use of intracavitary bleomycin for low-grade astrocytoma tumor cyst. Pediatric Neurosurgery 1999;31(5):246–50. | 10681679
Desjardins L, Maudet JM, Banchereau A, et al. [Eye manifestations and treatment of brain chordoma. Apropos of a case] [review] [46 refs] [French]. Journal Francais d Opthalmologie 1992;15(6–7):423–9. | 1294601
Daicker B, Zografos L, Muller O. [Homolateral episcleral metastasis or surgical seeding of a proton-irradiated ciliary body melanoma?] [German]. Klinische Monatsblatter fur Augenheilkunde 192:579–581. | 2841533
Batra PS, Lanza DC. Endoscopic power-assisted orbital exenteration. American Journal of Rhinology 1919:297–301. | 16011138
Spire M, Devouassoux MS, Kodjikian L, et al. Primary transpupillary thermotherapy for 18 small posterior pole uveal melanomas. American Journal of Ophthalmology 2006;141(5):840–849. | 16678505
Lee CT, Bilton SD, Famiglietti RM, et al. Treatment planning with protons for pediatric retinoblastoma, medulloblastoma, and pelvic sarcoma: how do protons compare with other conformal techniques? International Journal of Radiation Oncology, Biology, Physics 2005;63(2):362–72. | 16168831
Romani A, Baldeschi L, Genovesi-Ebert F, et al. Ultrasonographic follow-up of primary choroidal malignant melanoma after proton beam irradiation therapy. Ophthalmologica 1998;212 Suppl 1:50–2. | 9730751
Yock T, Schneider R, Friedmann A, et al. Proton radiotherapy for orbital rhabdomyosarcoma: clinical outcome and a dosimetric comparison with photons. International Journal of Radiation Oncology, Biology, Physics 2005;63(4):1161–8. | 15950401
Gragoudas ES, Goitein M, Koehler A, et al. Proton irradiation of malignant melanoma of the ciliary body. British Journal of Ophthalmology 1979;63(2):135–9. | 106873
Ito H, Kimura F, Shimizu H, et al. [Surgical resection for pancreatic cancer combined with preoperative carbon-ion beam irradiation] [Japanese]. Gan to Kagaku Ryoho [Japanese Journal of Cancer & Chemotherapy] 2004;31(11):1879–81. | 15553746
Hug EB, Muenter MW, Adams JA, et al. 3-D-conformal radiation therapy for pediatric giant cell tumors of the skull base. Strahlentherapie und Onkologie 2002;178(5):239–44. | 12082682
Ramonas KM, Conway RM, Daftari IK, et al. Successful treatment of intraocularly invasive conjunctival squamous cell carcinoma with proton beam therapy. Archives of Ophthalmology 2006;124(1):126–8. | 16401797
Dran G, Niesar E, Vandenbos F, et al. Chondroblastoma of the apex portion of petrousal bone. Childs Nervous System 2007;23(2):231–5. | 17115228
Feuvret L, Noel G, Calugaru V, et al. Chondromyxoid fibroma of the skull base: differential diagnosis and radiotherapy: two case reports and a review of the literature [review] [45 refs]. Acta Oncologica 2005;44(6):545–53. | 16165913
Zografos L, Ducrey N, Beati D, et al. Metastatic melanoma in the eye and orbit. Ophthalmology 2003;110(11):2245–56. | 14597536
Zografos L, Uffer S, Gailloud C, et al. [Melanoma of the conjunctiva and its treatment] [French]. Klinische Monatsblatter fur Augenheilkunde 196:285–289. | 2366455
Zografos L, Uffer S, Bercher L, et al. [Combined surgery, cryocoagulation and radiotherapy for treatment of melanoma of the conjunctiva] [French]. Klinische Monatsblatter fur Augenheilkunde 204:385–390. | 8051878
Tzortzidis F, Elahi F, Wright DC, et al. Patient outcome at long-term follow-up after aggressive microsurgical resection of cranial base chondrosarcomas. Neurosurgery 2006;58(6):1090-8;discussion 1090-8. | 16723888
Coltrera MD, Googe PB, Harrist TJ, et al. Chondrosarcoma of the temporal bone. Diagnosis and treatment of 13 cases and review of the literature. Cancer 1986;58(12):2689–96. | 3022910
Masiukova EM, Tun VG, Kulemzina MV. [Recurrence of esophageal cancer 9 years after radiotherapy with bremsstrahlung from a 25-MeV betatron] [Russian]. Voprosy Onkologii 1986;32(11):112–3. | 3097960
Grange JD, Duquesne N, Roubeyrol F, et al. [Double irradiation for macroscopic radioresistance or recurrence of melanomas of the posterior uvea: clinical, ballistic, therapeutic and prognostic aspects. Series of 19 cases among 462 patients] [French]. Journal Francais d Opthalmologie 1999;22(10):1054–63. | 10617843
Nukui F, Nagata M, Kurokawa J, et al. [A case of osteosarcoma in pelvic bone following radiation therapy for prostate cancer] [Japanese]. Nippon Hinyokika Gakkai Zasshi - Japanese Journal of Urology 2004;95(1):59–62. | 14978943
Raffel C, Wright DC, Gutin PH, et al. Cranial chordomas: clinical presentation and results of operative and radiation therapy in twenty-six patients. Neurosurgery 1985;17(5):703–10. | 4069325