# Table of Eligible Studies

Citation | PMID
Bladder
Miyanaga N, Ami Y, Ohtani M, et al. Clinical study of proton radiotherapy in urological cancers [Japanese]. Nippon Hinyokika Gakkai Zasshi - Japanese Journal of Urology 1990;81(2):251–7. | 2157915
Hata M, Miyanaga N, Tokuuye K, et al. Proton beam therapy for invasive bladder cancer: a prospective study of bladder-preserving therapy with combined radiotherapy and intra-arterial chemotherapy. International Journal of Radiation Oncology, Biology, Physics 2006;64(5):1371–9. | 16580495
Tsujii H, Akaza H, Ohtani M, et al. Preliminary results of bladder-preserving therapy with definitive radiotherapy and intraarterial infusion of chemotherapy. Strahlentherapie und Onkologie 1994;170 (9):531–7. | 7940124
Bone
Delaney TF, Park L, Goldberg SI, et al. Radiotherapy for local control of osteosarcoma. International Journal of Radiation Oncology, Biology, Physics 2005;61(2):492–8. | 15667972
Kamada T, Tsujii H, Tsuji H, et al. Efficacy and safety of carbon ion radiotherapy in bone and soft tissue sarcomas. Journal of Clinical Oncology 1920:4466–4471. | 12431970
Reimers M, Castro JR, Linstadt D, et al. Heavy charged particle therapy of bone and soft tissue sarcoma. A phase I–II trial of the University of California Lawrence Berkeley Laboratory and the Northern California Oncology Group. American Journal of Clinical Oncology 1986;9(6):488–93. | 2431614
Timmermann B, Schuck A, Niggli F, et al. Spot-scanning proton therapy for malignant soft tissue tumors in childhood: First experiences at the Paul Scherrer Institute. International Journal of Radiation Oncology, Biology, Physics 2007;67(2):497–504. | 17084557
Weber DC, Rutz HP, Bolsi A, et al. Spot scanning proton therapy in the curative treatment of adult patients with sarcoma: the Paul Scherrer Institute experience. International Journal of Radiation Oncology, Biology, Physics 2007;69(3):865–71. | 17606333
Zhang H, Yoshikawa K, Tamura K, et al. [(11)C]methionine positron emission tomography and survival in patients with bone and soft tissue sarcomas treated by carbon ion radiotherapy. Clinical Cancer Research 2004;10(5):1764–72. | 15014030
Breast
Bush DA, Slater JD, Garberoglio C, et al. A technique of partial breast irradiation utilizing proton beam radiotherapy: comparison with conformal x-ray therapy [see comment]. Cancer Journal 2007;13(2):114–8. | 17476139
Kozak KR, Smith BL, Adams J, et al. Accelerated partial-breast irradiation using proton beams: initial clinical experience. International Journal of Radiation Oncology, Biology, Physics2006;66(3):691–8. | 17011445
Gastrointestinal
Castro JR, Saunders WM, Quivey JM, et al. Clinical problems in radiotherapy of carcinoma of the pancreas. American Journal of Clinical Oncology 1982;5(6):579–87. | 6762086
Castro JR, Chen GT, Pitluck S, et al. Helium charged-particle radiotherapy of locally advanced carcinoma of the esophagus, stomach, and biliary tract. American Journal of Clinical Oncology 1983;6(6 ):629–37. | 6637875
Koyama S, Tsujii H, Yokota H, et al. Proton beam therapy for patients with esophageal carcinoma. Japanese Journal of Clinical Oncology 1994;24(3):144–53. | 8007424
Linstadt D, Quivey JM, Castro JR, et al. Comparison of helium-ion radiation therapy and split-course megavoltage irradiation for unresectable adenocarcinoma of the pancreas. Final report of a Northern California Oncology Group randomized prospective clinical trial. Radiology 1988;168(1):261–4. | 3132732
Schoenthaler R, Phillips TL, Castro J, et al. Carcinoma of the extrahepatic bile ducts. The University of California at San Francisco experience. Annals of Surgery 1994;219(3):267–74. | 8147607
Schoenthaler R, Castro JR, Halberg FE, et al. Definitive postoperative irradiation of bile duct carcinoma with charged particles and/or photons. International Journal of Radiation Oncology, Biology, Physics 1993;27(1):75–82. | 8365945
Sugahara S, Tujii H, Tuji H, et al. [The value of frequent positioning of treatment field in radiotherapy of esophageal cancer] [Japanese]. Nippon Igaku Hoshasen Gakkai Zasshi - Nippon Acta Radiologica 1992;52(9):1308–14. | 1437536
Sugahara S, Tokuuye K, Okumura T, et al. Clinical results of proton beam therapy for cancer of the esophagus. International Journal of Radiation Oncology, Biology, Physics 2005;61(1):76–84. | 15629597
Head and Neck
Al-Mefty O, Borba LA. Skull base chordomas: a management challenge. Journal of Neurosurgery 1997;86(2):182–9. | 9010416
Austin-Seymour M, Munzenrider J, Goitein M, et al. Fractionated proton radiation therapy of chordoma and low-grade chondrosarcoma of the base of the skull. Journal of Neurosurgery 1989;70(1):13–7. | 2535872
Austin-Seymour M, Munzenrider J, Linggood R, et al. Fractionated proton radiation therapy of cranial and intracranial tumors. American Journal of Clinical Oncology 1990;13(4):327–30. | 2165739
Benk V, Liebsch NJ, Munzenrider JE, et al. Base of skull and cervical spine chordomas in children treated by high-dose irradiation. International Journal of Radiation Oncology, Biology, Physics 1995;31(3):577–81. | 7852123
Berson AM, Castro JR, Petti P, et al. Charged particle irradiation of chordoma and chondrosarcoma of the base of skull and cervical spine: the Lawrence Berkeley Laboratory experience. International Journal of Radiation Oncology, Biology, Physics 1988;15(3):559–65. | 3138208
Castro JR, Linstadt DE, Bahary JP, et al. Experience in charged particle irradiation of tumors of the skull base: 1977–1992 [see comment] [review] [35 refs]. International Journal of Radiation Oncology, Biology, Physics 1994;29(4):647–55. | 8040010
Castro JR, Reimers MM. Charged particle radiotherapy of selected tumors in the head and neck. International Journal of Radiation Oncology, Biology, Physics 1988;14(4):711–20. | 3350726
Castro JR, Phillips TL, Prados M, et al. Neon heavy charged particle radiotherapy of glioblastoma of the brain. International Journal of Radiation Oncology, Biology, Physics 1997;38(2):257–61. | 9226311
Colli B, Al-Mefty O. Chordomas of the craniocervical junction: follow-up review and prognostic factors. Journal of Neurosurgery 2001;95(6):933–43. | 11765837
Debus J, Haberer T, Schulz-Ertner D, et al. [Carbon ion irradiation of skull base tumors at GSI. First clinical results and future perspectives] [German]. Strahlentherapie und Onkologie 2000;176(5):211–6. | 10847117
Fagundes MA, Hug EB, Liebsch NJ, et al. Radiation therapy for chordomas of the base of skull and cervical spine: patterns of failure and outcome after relapse. International Journal of Radiation Oncology, Biology, Physics 1995;33(3):579–84. | 7558946
Fitzek MM, Thornton AF, Harsh G, et al. Dose-escalation with proton/photon irradiation for Daumas-Duport lower-grade glioma: results of an institutional phase I/II trial. International Journal of Radiation Oncology, Biology, Physics 2001;51(1):131–7. | 11516862
Fitzek MM, Thornton AF, Varvares M, et al. Neuroendocrine tumors of the sinonasal tract. Results of a prospective study incorporating chemotherapy, surgery, and combined proton-photon radiotherapy. Cancer 2002;94(10):2623–34. | 12173330
Fuss M, Hug EB, Schaefer RA, et al. Proton radiation therapy (PRT) for pediatric optic pathway gliomas: comparison with 3D planned conventional photons and a standard photon technique. International Journal of Radiation Oncology, Biology, Physics 1999;45(5):1117–26. | 10613303
Gridley DS, Loredo LN, Slater JD, et al. Pilot evaluation of cytokine levels in patients undergoing radiotherapy for brain tumor. Cancer Detection & Prevention 1998;22(1):20–9. | 9466045
Hasegawa A, Mizoe JE, Mizota A, et al. Outcomes of visual acuity in carbon ion radiotherapy: analysis of dose-volume histograms and prognostic factors. International Journal of Radiation Oncology, Biology, Physics 2006;64(2):396–401. | 16182466
Hug EB, DeVries A, Thornton AF, et al. Management of atypical and malignant meningiomas: role of high-dose, 3D-conformal radiation therapy. Journal of Neuro-Oncology 2000;48(2):151–60. | 11083080
Hug EB, Loredo LN, Slater JD, et al. Proton radiation therapy for chordomas and chondrosarcomas of the skull base [see comment]. Journal of Neurosurgery 1999;91(3):432–9. | 10470818
Hug EB, Muenter MW, Archambeau JO, et al. Conformal proton radiation therapy for pediatric low-grade astrocytomas. Strahlentherapie und Onkologie 2002;78(1):10–17. | 11977386
Hug EB, Sweeney RA, Nurre PM, et al. Proton radiotherapy in management of pediatric base of skull tumors. International Journal of Radiation Oncology, Biology, Physics 2002;52(4):1017–24. | 11958897
Igaki H, Tokuuye K, Okumura T, et al. Clinical results of proton beam therapy for skull base chordoma [review] [38 refs]. International Journal of Radiation Oncology, Biology, Physics 2004;60(4):1120–6. | 15519783
Kishimoto R, Mizoe JE, Komatsu S, et al. MR imaging of brain injury induced by carbon ion radiotherapy for head and neck tumors. Magnetic Resonance in Medical Sciences 2005;4(4):159–64. | 16543700
McAllister B, Archambeau JO, Nguyen MC, et al. Proton therapy for pediatric cranial tumors: preliminary report on treatment and disease-related morbidities. International Journal of Radiation Oncology, Biology, Physics 1997;39(2):455–60. | 9308950
Mizoe JE, Tsujii H, Hasegawa A, et al. Phase I/II clinical trial of carbon ion radiotherapy for malignant gliomas: combined X-ray radiotherapy, chemotherapy, and carbon ion radiotherapy. International Journal of Radiation Oncology, Biology, Physics 2007;69(2):390–6. | 17459607
Mizoe JE, Tsujii H, Kamada T, et al. Dose escalation study of carbon ion radiotherapy for locally advanced head-and-neck cancer [see comment]. International Journal of Radiation Oncology, Biology, Physics 2004;60(2):358–64. | 15380567
Nishimura H, Ogino T, Kawashima M, et al. Proton-beam therapy for olfactory neuroblastoma. International Journal of Radiation Oncology, Biology, Physics 2007;68(3):758–62. | 17398027
Noel G, Feuvret L, Calugaru V, et al. Chordomas of the base of the skull and upper cervical spine. One hundred patients irradiated by a 3D conformal technique combining photon and proton beams. Acta Oncologica 2005;44(7):700–8. | 16227160
Noel G, Feuvret L, Dhermain F, et al. [Chordomas of the base of the skull and upper cervical spine. 100 patients irradiated by a 3D conformal technique combining photon and proton beams] [French]. Cancer Radiotherapie 2005;9(3):61–74. | 15979920
Noel G, Feuvret L, Ferrand R, et al. Radiotherapeutic factors in the management of cervical-basal chordomas and chondrosarcomas. Neurosurgery 2004;55(6):1252–60;discussion 1260–2. | 15574207
Noel G, Habrand JL, Helfre S, et al. Proton beam therapy in the management of central nervous system tumors in childhood: the preliminary experience of the Centre de Protontherapie d'Orsay. Medical & Pediatric Oncology 2003;40(5):309–15. | 12652619
Noel G, Habrand JL, Jauffret E, et al. Radiation therapy for chordoma and chondrosarcoma of the skull base and the cervical spine. Prognostic factors and patterns of failure. Strahlentherapie und Onkologie 2003;179(4):241–8. | 12707713
Noel G, Habrand JL, Mammar H, et al. Combination of photon and proton radiation therapy for chordomas and chondrosarcomas of the skull base: the Centre de Protontherapie D'Orsay experience. International Journal of Radiation Oncology, Biology, Physics 2001;51(2):392–8. | 11567813
Noel G, Jauffret E, Crevoisier RD, et al. [Radiation therapy for chordomas and chondrosarcomas of the base of the skull and cervical spine] [French]. Bulletin du Cancer 2002;89(7–8):713–23. | 12206985
O'Connell JX, Renard LG, Liebsch NJ, et al. Base of skull chordoma. A correlative study of histologic and clinical features of 62 cases. Cancer 1994;74(8):2261–7. | 7922977
Pommier P, Liebsch NJ, Deschler DG, et al. Proton beam radiation therapy for skull base adenoid cystic carcinoma. Archives of Otolaryngology—Head & Neck Surgery 2006;132(11):1242–9. | 17116822
Rosenberg AE, Nielsen GP, Keel SB, et al. Chondrosarcoma of the base of the skull: a clinicopathologic study of 200 cases with emphasis on its distinction from chordoma. American Journal of Surgical Pathology 1999;23(11):1370–8. | 10555005
Santoni R, Liebsch N, Finkelstein DM, et al. Temporal lobe (TL) damage following surgery and high-dose photon and proton irradiation in 96 patients affected by chordomas and chondrosarcomas of the base of the skull. International Journal of Radiation Oncology, Biology, Physics 1998;41(1):59–68. | 9588918
Saunders WM, Chen GT, ustin-Seymour M, et al. Precision, high dose radiotherapy. II. Helium ion treatment of tumors adjacent to critical central nervous system structures. International Journal of Radiation Oncology, Biology, Physics 2002;11(7):1339–47. | 4008290
Schulz-Ertner D, Haberer T, Jakel O, et al. Radiotherapy for chordomas and low-grade chondrosarcomas of the skull base with carbon ions. International Journal of Radiation Oncology, Biology, Physics 2002;53(1):36–42. | 12007939
Schulz-Ertner D, Haberer T, Scholz M, et al. Acute radiation-induced toxicity of heavy ion radiotherapy delivered with intensity modulated pencil beam scanning in patients with base of skull tumors. Radiotherapy & Oncology 2002;64(2):189–95. | 12242129
Schulz-Ertner D, Karger CP, Feuerhake A, et al. Effectiveness of carbon ion radiotherapy in the treatment of skull-base chordomas. International Journal of Radiation Oncology, Biology, Physics2007;68(2):449–57. | 17363188
Schulz-Ertner D, Nikoghosyan A, Didinger B, et al. Therapy strategies for locally advanced adenoid cystic carcinomas using modern radiation therapy techniques. Cancer 2005;104(2):338–44. | 15937907
Schulz-Ertner D, Nikoghosyan A, Didinger B, et al. Carbon ion radiation therapy for chordomas and low grade chondrosarcomas—current status of the clinical trials at GSI. Radiotherapy & Oncology 2004;73 Suppl 2:S53–6. | 15971310
Schulz-Ertner D, Nikoghosyan A, Jakel O, et al. Feasibility and toxicity of combined photon and carbon ion radiotherapy for locally advanced adenoid cystic carcinomas. International Journal of Radiation Oncology, Biology, Physics 2003;56(2):391–8. | 12738314
Schulz-Ertner D, Nikoghosyan A, Thilmann C, et al. Carbon ion radiotherapy for chordomas and low-grade chondrosarcomas of the skull base. Results in 67 patients. Strahlentherapie und Onkologie 2003;179(9):598–605. | 14628125
Schulz-Ertner D, Nikoghosyan A, Thilmann C, et al. Results of carbon ion radiotherapy in 152 patients. International Journal of Radiation Oncology, Biology, Physics 2004;58(2):631–40. | 14751537
Slater JD, ustin-Seymour M, Munzenrider J, et al. Endocrine function following high dose proton therapy for tumors of the upper clivus. International Journal of Radiation Oncology, Biology, Physics 1988;15(3):607–11. | 3138212
Slater JD, Yonemoto LT, Mantik DW, et al. Proton radiation for treatment of cancer of the oropharynx: early experience at Loma Linda University Medical Center using a concomitant boost technique. International Journal of Radiation Oncology, Biology, Physics 2005;62(2):494–500. | 15890592
Suit HD, Goitein M, Munzenrider J, et al. Definitive radiation therapy for chordoma and chondrosarcoma of base of skull and cervical spine. Journal of Neurosurgery 1982;56(3):377–85. | 7057235
Terahara A, Niemierko A, Goitein M, et al. Analysis of the relationship between tumor dose inhomogeneity and local control in patients with skull base chordoma. International Journal of Radiation Oncology, Biology, Physics 1999;45(2):351–8. | 10487555
Tokuuye K, Akine Y, Kagei K, et al. Proton therapy for head and neck malignancies at Tsukuba. Strahlentherapie und Onkologie 2004;180(2):96–101. | 14762662
Weber DC, Chan AW, Lessell S, et al. Visual outcome of accelerated fractionated radiation for advanced sinonasal malignancies employing photons/protons. Radiotherapy & Oncology 2006;81(3):243–9. | 17050017
Weber DC, Rutz HP, Pedroni ES, et al. Results of spot-scanning proton radiation therapy for chordoma and chondrosarcoma of the skull base: the Paul Scherrer Institut experience. International Journal of Radiation Oncology, Biology, Physics 2005;63(2):401–9. | 16168833
Yoshii Y, Maki Y, Narushima A, et al. [Use of radiotherapy by high-energy protons in the postoperative treatment of brain tumors] [Japanese]. Neurologia Medico-Chirurgica 1986;26(3):219–26. | 2426616
Yoshii Y, Takano S, Tsurushima H, et al. Normal brain damage after radiotherapy of brain tumours. Clinical Oncology (Royal College of Radiologists) 1991;3(5):278–82. | 1657115
Zhang H, Yoshikawa K, Tamura K, et al. Carbon-11-methionine positron emission tomography imaging of chordoma. Skeletal Radiology 2004;33(9):524–30. | 15483754
Liver (Hepatocellular carcinoma)
Ahmadi T, Itai Y, Onaya H, et al. CT evaluation of hepatic injury following proton beam irradiation: appearance, enhancement, and 3D size reduction pattern. Journal of Computer Assisted Tomography 1999;23(5):655–63. | 10524841
Bush DA, Hillebrand DJ, Slater JM, Slater JD. High-dose proton beam radiotherapy of hepatocellular carcinoma: preliminary results of a phase II trial. Gastroenterology 2004;127(5 Suppl 1):S189–93. | 15508084
Chiba T, Tokuuye K, Matsuzaki Y, et al. Proton beam therapy for hepatocellular carcinoma: a retrospective review of 162 patients. Clinical Cancer Research 2005;11(10):3799–805. | 15897579
Hashimoto T, Tokuuye K, Fukumitsu N, et al. Repeated proton beam therapy for hepatocellular carcinoma. International Journal of Radiation Oncology, Biology, Physics 2006;65(1):196–202. | 16563656
Hata M, Tokuuye K, Sugahara S et al. Proton beam therapy for hepatocellular carcinoma with limited treatment options. Cancer 107 (3):591–8, 2006 | 16804931
Hata M, Tokuuye K, Sugahara S et al. Proton beam therapy for aged patients with hepatocellular carcinoma. International Journal of Radiation Oncology, Biology, Physics 69 (3):805–12, 2007 | 17524568
Hata M, Tokuuye K, Sugahara S, et al. Proton beam therapy for hepatocellular carcinoma patients with severe cirrhosis. Strahlentherapie und Onkologie 2006;182(12):713–20. | 17149578
Hata M, Tokuuye K, Sugahara S, et al. Proton beam therapy for hepatocellular carcinoma with portal vein tumor thrombus. Cancer 2005;104(4):794–801. | 15981284
Kato H, Tsujii H, Miyamoto T, et al. Results of the first prospective study of carbon ion radiotherapy for hepatocellular carcinoma with liver cirrhosis. International Journal of Radiation Oncology, Biology, Physics 2004;59(5):1468–76. | 15275734
Kawashima M, Furuse J, Nishio T et al. Phase II study of radiotherapy employing proton beam for hepatocellular carcinoma. Journal of Clinical Oncology 2005;23(9):1839–46. | 15774777
Matsuzaki Y, Osuga T, Saito Y, et al. A new, effective, and safe therapeutic option using proton irradiation for hepatocellular carcinoma. Gastroenterology 1994;106(4):1032–41. | 7511552
Niizawa G, Ikegami T, Matsuzaki Y, et al. Monitoring of hepatocellular carcinoma, following proton radiotherapy, with contrast-enhanced color Doppler ultrasonography. Journal of Gastroenterology 2005;40(3):283–90. | 15830288
Tsuji H, Okumura T, Maruhashi A, et al. [Dose-volume histogram analysis of patients with hepatocellular carcinoma regarding changes in liver function after proton therapy] [Japanese]. Nippon Igaku Hoshasen Gakkai Zasshi - Nippon Acta Radiologica 1995;55(5):322–8. | 7784153
Lung
Bonnet RB, Bush D, Cheek GA, et al. Effects of proton and combined proton/photon beam radiation on pulmonary function in patients with resectable but medically inoperable non-small cell lung cancer. Chest 2001;120(6):1803–10. | 11742905
Bush DA, Dunbar RD, Bonnet R, et al. Pulmonary injury from proton and conventional radiotherapy as revealed by CT. AJR American Journal of Roentgenology 1999;172(3):735–9. | 10063871
Bush DA, Slater JD, Bonnet R, et al. Proton-beam radiotherapy for early-stage lung cancer. Chest 1999;116(5):1313–9. | 10559093
Bush DA, Slater JD, Shin BB, et al. Hypofractionated proton beam radiotherapy for stage I lung cancer. Chest 2004;126(4):1198–203. | 15486383
Hata M, Tokuuye K, Kagei K, et al. Hypofractionated high-dose proton beam therapy for stage I non-small-cell lung cancer: preliminary results of a phase I/II clinical study. International Journal of Radiation Oncology, Biology, Physics 2007;68(3):786–93. | 17379439
Homma T, Ohtsu I, Tomioka S, et al. [Quantitative analysis of pulmonary functional damage due to heavy ion particle irradiation therapy for lung cancer] [Japanese]. Nihon Kokyuki Gakkai Zasshi 1999;37(2):97–101. | 10214036
Kadono K, Homma T, Kamahara K, et al. Effect of heavy-ion radiotherapy on pulmonary function in stage I non-small cell lung cancer patients. Chest 2002;122(6):1925–32. | 12475828
Koto M, Miyamoto T, Yamamoto N, et al. Local control and recurrence of stage I non-small cell lung cancer after carbon ion radiotherapy [see comment]. Radiotherapy & Oncology 2004;71(2):147–56. | 15110447
Miyamoto 2007 (no record of UI number in file) | 17903054
Miyamoto T, Baba M, Yamamoto N, et al. Curative treatment of Stage I non-small-cell lung cancer with carbon ion beams using a hypofractionated regimen. International Journal of Radiation Oncology, Biology, Physics 2007;67(3):750–8. | 17293232
Miyamoto T, Yamamoto N, Koto M, et al. [Heavy-ion therapy for non-small cell lung cancer] [review] [5 refs] [Japanese]. Nippon Geka Gakkai Zasshi Journal of Japan Surgical Society 2002;103(2):250–5. | 11904989
Miyamoto T, Yamamoto N, Nishimura H, et al. Carbon ion radiotherapy for stage I non-small cell lung cancer. Radiotherapy & Oncology 2003;66(2):127–40. | 12648784
Miyamoto T. [Heavy ion therapy for non-small cell lung cancer--new, radical radiotherapy for advanced-age patients as an alternative to surgery] [Japanese]. Gan to Kagaku Ryoho [Japanese Journal of Cancer & Chemotherapy] 2003;30(2):209–14. | 12610868
Nihei K, Ogino T, Ishikura S, et al. High-dose proton beam therapy for Stage I non-small-cell lung cancer. International Journal of Radiation Oncology, Biology, Physics 2006;65(1):107–11. | 16458447
Nishimura H, Miyamoto T, Yamamoto N, et al. Radiographic pulmonary and pleural changes after carbon ion irradiation. International Journal of Radiation Oncology, Biology, Physics 2003;55(4):861–6. | 12605963
Satoh H, Okumura T, Yamashita YT, et al. Proton irradiation for non-small cell lung cancer. Archives of Internal Medicine 1998;158(12):1379–80. | 9645836
Shioyama Y, Tokuuye K, Okumura T, et al. Clinical evaluation of proton radiotherapy for non- small-cell lung cancer. International Journal of Radiation Oncology, Biology, Physics 2003;56(1):7–13. | 12694818
Eye
Bechrakis NE, Hocht S, Martus P, et al. [Endoresection following proton beam irradiation of large uveal melanomas] [German]. Ophthalmologe 2004;101(4):370 –6. | 15067418
Bercher L, Zografos L, Egger E, et al. [Treatment of exterior extension of choroid melanomas by accelerated proton beams] [French]. Klinische Monatsblatter fur Augenheilkunde 1992:440–443 | 1319525
Boudinet M, Berges O, Le Huerou JY, et al. Quantitative echography in the follow-up of patients treated with proton-beam irradiation for primary choroidal melanomas. Ultrasound in Medicine & Biology 2007;33(7):1046–56. | 17448588
Brovkina AF, Zarubei GD. Ciliochoroidal melanomas treated with a narrow medical proton beam. Arch Ophthalmol 1986 Mar;104(3):402–4. | 3006648
Castro JR, Char DH, Petti PL, et al. 15 years experience with helium ion radiotherapy for uveal melanoma. International Journal of Radiation Oncology, Biology, Physics 1997;39(5):989–96. | 9392536
Char DH, Bove R, Phillips TL. Laser and proton radiation to reduce uveal melanoma- associated exudative retinal detachments. American Journal of Ophthalmology 2003;136(1):180–2. | 12834689
Char DH, Castro JR, Kroll SM, et al. Five-year follow-up of helium ion therapy for uveal melanoma. Archives of Ophthalmology 1990;108(2):209–14. | 2302103
Char DH, Castro JR, Quivey JM, et al. Uveal melanoma radiation. 125I brachytherapy versus helium ion irradiation. Ophthalmology 1989;96(12):1708–15. | 2695875
Char DH, Castro JR. Helium ion therapy for choroidal melanoma. Archives of Ophthalmology 1982;100(6):935–8. | 7092631
Char DH, Kroll S, Quivey JM, et al. Long term visual outcome of radiated uveal melanomas in eyes eligible for randomisation to enucleation versus brachytherapy. British Journal of Ophthalmology 1996;80(2):117–24. | 8814740
Char DH, Kroll SM, Castro J. Long-term follow-up after uveal melanoma charged particle therapy. Transactions of the American Ophthalmological Society 1997;95:171–87; discussion 187–91. | 9440169
Char DH, Kroll SM, Castro J. Ten-year follow-up of helium ion therapy for uveal melanoma. American Journal of Ophthalmology 1998;125(1):81–9. | 9437317
Char DH, Quivey JM, Castro JR, et al. Helium ions versus iodine 125 brachytherapy in the management of uveal melanoma. A prospective, randomized, dynamically balanced trial. Ophthalmology 1993;100(10):1547–54. | 8414414
Char DH, Saunders W, Castro JR, et al. Helium ion therapy for choroidal melanoma. Ophthalmology 1983;90(10):1219–25. | 6657197
Char DH. Radiation therapy for uveal melanomas involving the ciliary body. Transactions of the Ophthalmological Societies of the United Kingdom 1986;105(Pt 2):252–6. | 3467500
Courdi A, Caujolle JP, Grange JD, et al. Results of proton therapy of uveal melanomas treated in Nice. International Journal of Radiation Oncology, Biology, Physics 1999;45(1):5– 11. | 10477000
Crawford JB, Char DH. Histopathology of uveal melanomas treated with charged particle radiation. Ophthalmology 1987 Jun;94(6):639–43. | 3627712
Daftari IK, Char DH, Verhey LJ, et al. Anterior segment sparing to reduce charged particle radiotherapy complications in uveal melanoma. International Journal of Radiation Oncology, Biology, Physics 1997;39(5):997–1010. | 9392537
Damato B, Kacperek A, Chopra M, et al. Proton beam radiotherapy of choroidal melanoma: the Liverpool-Clatterbridge experience. Int J Radiat Oncol Biol Phys 2005 Aug 1;62(5):1405– 11. | 16029800
Damato B, Kacperek A, Chopra M, et al. Proton beam radiotherapy of iris melanoma. Int J Radiat Oncol Biol Phys 2005 Sep 1;63(1):109–15. | 16111578
Dendale R, Lumbroso-Le RL, Noel G, et al. Proton beam radiotherapy for uveal melanoma: results of Curie Institut-Orsay proton therapy center (ICPO). International Journal of Radiation Oncology, Biology, Physics 2006;65(3):780 –7. | 16647221
Desjardins L, Levy C, D'Hermies F, et al. [Initial results of proton therapy in choroidal melanoma at the d'Orsey Center for Proton Therapy; the first 464 cases] [French]. Cancer Radiotherapie 1997;1(3):222–6. | 9295876
Desjardins L, Lumbroso L, Levy C, et al. [Treatment of uveal melanoma with iodine 125 plaques or proton beam therapy: indications and comparison of local recurrence rates] [French]. Journal Francais d Opthalmologie 2003;26(3):269–76. | 12746603
Desjardins L, Lumbroso-Le RL, Levy-Gabriel C, et al. Combined proton beam radiotherapy and transpupillary thermotherapy for large uveal melanomas: a randomized study of 151 patients [see comment]. Ophthalmic Research 2006;38(5):255–60. | 16888407
Egan KM, Gragoudas ES, Seddon JM, et al. The risk of enucleation after proton beam irradiation of uveal melanoma. Ophthalmology 1989;96(9):1377–82; discussion 1382–3. | 2550868
Egan KM, Gragoudas ES, Seddon JM, et al. Smoking and the risk of early metastases from uveal melanoma. Ophthalmology 1992;99(4):537–41. | 1584571
Egan KM, Quinn JL, Gragoudas ES. Childbearing history associated with improved survival in choroidal melanoma. Archives of Ophthalmology 1999;117(7):939–42. | 10408460
Egan KM, Ryan LM, Gragoudas ES. Survival implications of enucleation after definitive radiotherapy for choroidal melanoma: an example of regression on time-dependent covariates. Archives of Ophthalmology 1998;116(3):366–70. | 9514491
Egan KM, Walsh SM, Seddon JM, et al. An evaluation of the influence of reproductive factors on the risk of metastases from uveal melanoma. Ophthalmology 1993;100(8):1160 – 5;discussion 1166. | 8341495
Egger E, Schalenbourg A, Zografos L, et al. Maximizing local tumor control and survival after proton beam radiotherapy of uveal melanoma. Int J Radiat Oncol Biol Phys 2001 Sep 1;51(1):138–47. | 11516863
Egger E, Zografos L, Schalenbourg A, et al. Eye retention after proton beam radiotherapy for uveal melanoma. Int J Radiat Oncol Biol Phys 2003 Mar 15;55(4):867–80. | 12605964
Foss AJ, Whelehan I, Hungerford JL, et al. Predictive factors for the development of rubeosis following proton beam radiotherapy for uveal melanoma. British Journal of Ophthalmology 1997;81(9):748–54. | 9422926
Gambrelle J, Kodjikian L, Rouberol F, et al. [Ciliary body melanomas. Survival and prognostic aspects after brachytherapy or proton therapy] [French]. Journal Francais d Opthalmologie 2004;27(1):40–7. | 14968076
Glynn RJ, Seddon JM, Gragoudas ES, et al. Evaluation of tumor regression and other prognostic factors for early and late metastasis after proton irradiation of uveal melanoma. Ophthalmology 1989;96(10):1566–73. | 2685710
Gragoudas ES, Egan KM, Arrigg PG, et al. Cataract extraction after proton beam irradiation for malignant melanoma of the eye [see comment]. Archives of Ophthalmology 1992;110(4):475–9. | 1562251
Gragoudas ES, Egan KM, Saornil MA, et al. The time course of irradiation changes in proton beam-treated uveal melanomas. Ophthalmology 1993;100(10):1555–9; discussion 1560. | 8414415
Gragoudas ES, Egan KM, Seddon JM, et al. Intraocular recurrence of uveal melanoma after proton beam irradiation. Ophthalmology 1992;99(5):760–6. | 1594223
Gragoudas ES, Egan KM, Walsh SM, et al. Lens changes after proton beam irradiation for uveal melanoma. American Journal of Ophthalmology 1995;119(2):157–64. | 7832221
Gragoudas ES, Goitein M, Seddon J, et al. Preliminary results of proton beam irradiation of macular and paramacular melanomas. British Journal of Ophthalmology 1984;68(7):479–85. | 6329261
Gragoudas ES, Goitein M, Verhey L, et al. Proton beam irradiation of uveal melanomas. Results of 5 1/2-year study. Archives of Ophthalmology 1982;100(6):928–34. | 6284097
Gragoudas ES, Lane AM, Munzenrider J, et al. Long-term risk of local failure after proton therapy for choroidal/ciliary body melanoma. Transactions of the American Ophthalmological Society 2002;100:43–8; discussion 48–9. | 12545676
Gragoudas ES, Lane AM, Regan S, et al. A randomized controlled trial of varying radiation doses in the treatment of choroidal melanoma. Archives of Ophthalmology 2000;118(6):773– 8. | 10865313
Gragoudas ES, Li W, Lane AM, et al. Risk factors for radiation maculopathy and papillopathy after intraocular irradiation. Ophthalmology 1999;106(8):1571–7; discussion 1577–8. | 10442906
Gragoudas ES, Seddon J, Goitein, et al. Current results of proton beam irradiation of uveal melanomas. Ophthalmology | 2984625
Gragoudas ES, Seddon JM, Egan K, et al. Long-term results of proton beam irradiated uveal melanomas. Ophthalmology 1987;94(4):349–53. | 3035451
Gragoudas ES, Seddon JM, Egan KM, et al. Metastasis from uveal melanoma after proton beam irradiation. Ophthalmology 1988;95(7):992–9. | 2845324
Gragoudas ES, Seddon JM, Egan KM, et al. Prognostic factors for metastasis following proton beam irradiation of uveal melanomas. Ophthalmology 1986;93(5):675–80. | 3014416
Guyer DR, Mukai S, Egan KM, et al. Radiation maculopathy after proton beam irradiation for choroidal melanoma. Ophthalmology 1992;99(8):1278–85. | 1325044
Hamrouni Z, Levy C, Lumbroso L, et al. [Results of treating uveal melanoma with proton beam radiation: 10-year follow-up] [French]. Journal Francais d Opthalmologie 2005;28(8):833–9. | 16249762
Harbour JW, Char DH, Kroll S, et al. Metastatic risk for distinct patterns of postirradiation local recurrence of posterior uveal melanoma. Ophthalmology 1997;104(11):1785–92; discussion 1792–3. | 9373108
Hirasawa N, Tsuji H, Ishikawa H, et al. Risk factors for neovascular glaucoma after carbon ion radiotherapy of choroidal melanoma using dose-volume histogram analysis. International Journal of Radiation Oncology, Biology, Physics 2007;67(2):538–43. | 17141971
Hocht S, Bechrakis NE, Nausner M, et al. Proton therapy of uveal melanomas in Berlin. 5 years of experience at the Hahn-Meitner Institute [see comment]. Strahlentherapie und Onkologie 2004;180(7):419–24. | 15241529
Hungerford JL, Foss AJ, Whelahan I, et al. Side effects of photon and proton radiotherapy for ocular melanoma. Frontiers of Radiation Therapy & Oncology 1997;30:287–93. | 9205912
Kent D, Noonan CP, Damato BE. Management of Irish patients with intraocular melanoma referred to Liverpool, England. Acta Ophthalmologica Scandinavica 1998;76(5):584–8. | 9826044
Kim MK, Char DH, Castro JL, et al. Neovascular glaucoma after helium ion irradiation for uveal melanoma. Ophthalmology 1986;93(2):189–93. | 2419816
Kodjikian L, Roy P, Rouberol F, et al. Survival after proton-beam irradiation of uveal melanomas. American Journal of Ophthalmology 2004;137(6):1002–10. | 15183783
Li W, Gragoudas ES, Egan KM. Metastatic melanoma death rates by anatomic site after proton beam irradiation for uveal melanoma. Archives of Ophthalmology 2000;118(8):1066– 70. | 10922199
Li W, Gragoudas ES, Egan KM. Tumor basal area and metastatic death after proton beam irradiation for choroidal melanoma. Archives of Ophthalmology 2003;121(1):68–72. | 12523887
Linstadt D, Castro J, Char D, et al. Long-term results of helium ion irradiation of uveal melanoma. International Journal of Radiation Oncology, Biology, Physics 1990:613–618. | 2120158
Linstadt D, Char DH, Castro JR, et al. Vision following helium ion radiotherapy of uveal melanoma: a Northern California Oncology Group study [see comment]. International Journal of Radiation Oncology, Biology, Physics 1988;15(2):347–52. | 3403315
Lovato AA, Char DH, Castro JR, et al. The effect of silicone nasolacrimal intubation on epiphora after helium ion irradiation of uveal melanomas. American Journal of Ophthalmology 1989;108(4):431–4. | 2801862
Lumbroso L, Desjardins L, Levy C, et al. Intraocular inflammation after proton beam irradiation for uveal melanoma. British Journal of Ophthalmology 2001;85(11):1305–8. | 11673294
Lumbroso L, Levy C, Plancher C, et al. [Results of proton beam irradiation for treatment of choroidal melanoma] [French]. Journal Francais d Opthalmologie 2002;25(3):290–7. | 11941255
Lumbroso-Le RL, Delacroix S, Dendale R, et al. Proton beam therapy for iris melanomas. Eye 1920:1300–1305. | 16294207
Marucci L, Lane AM, Li W, et al. Conservation treatment of the eye: Conformal proton reirradiation for recurrent uveal melanoma. International Journal of Radiation Oncology, Biology, Physics 2006;64(4):1018–22. | 16376492
Meecham WJ, Char DH, Chen GT, et al. Correlation of visual field, treatment fields, and dose in helium ion irradiation of uveal melanoma. American Journal of Ophthalmology 1985;100(5):658–65. | 4061545
Meecham WJ, Char DH, Kroll S, et al. Anterior segment complications after helium ion radiation therapy for uveal melanoma. Radiation cataract. Archives of Ophthalmology 1994;112(2):197–203. | 8311772
Meyer A, Levy C, Blondel J, et al. [Optic neuropathy after proton-beam therapy for malignant choroidal melanoma] [French]. Journal Francais d Opthalmologie 2000;23(6):543–53. | 10880919
Munzenrider JE, Gragoudas ES, Seddon JM, et al. Conservative treatment of uveal melanoma: probability of eye retention after proton treatment. International Journal of Radiation Oncology, Biology, Physics 1988;15(3):553–8. | 2843486
Munzenrider JE, Verhey LJ, Gragoudas ES, et al. Conservative treatment of uveal melanoma: local recurrence after proton beam therapy. International Journal of Radiation Oncology, Biology, Physics 1989;17(3):493–8. | 2550395
Naeser P, Blomquist E, Montelius A, et al. Proton irradiation of malignant uveal melanoma. A five year follow-up of patients treated in Uppsala, Sweden. Upsala Journal of Medical Sciences 1998;103(3):203–11. | 10052109
Nowakowski VA, Ivery G, Castro JR, et al. Uveal melanoma: development of metastases after helium ion irradiation. Radiology 1991;178(1):277–80. | 1898536
Park SS, Walsh SM, Gragoudas ES. Visual-field deficits associated with proton beam irradiation for parapapillary choroidal melanoma [erratum appears in Ophthalmology 1996 May;103(5):699]. Ophthalmology 1996;103(1):110–6. | 8628541
Ravozzoni L, Mosci C, Polizzi A, et al. Ultrasonographic follow-up of patients with choroidal melanoma following conservative treatment. Ophthalmologica 1998;212(Suppl 1):77–8. | 9730759
Regan S, Judge HE, Gragoudas ES, et al. Iris color as a prognostic factor in ocular melanoma. Archives of Ophthalmology 1999;117(6):811–4 | 10369595
Romani A, Baldeschi L, Genovesi-Ebert F, et al. Ultrasonographic and angiographic follow-up of primary choroidal malignant melanoma after proton beam irradiation therapy. Ophthalmologica 19998;212(Suppl 1):47–9. | 9730750
Rundle P, Singh AD, Rennie I. Proton beam therapy for iris melanoma: a review of 15 cases. Eye 2007;21(1):79–82. | 16410818
Saunders WM, Char DH, Quivey JM, et al. Precision, high dose radiotherapy: helium ion treatment of uveal melanoma. International Journal of Radiation Oncology, Biology, Physics 1985;11(2):227–33. | 2579050
Schlienger P, Habrand JL, Schwartz L, et al. Initial results with one-year minimum follow-up of the first 146 patients with a uveal melanoma treated with protons at CPO (Orsay). Bulletin du Cancer Radiotherapie 1996;83(Suppl):212s–4s. | 8949782
Seddon JM, Gragoudas ES, Albert DM, et al. Comparison of survival rates for patients with uveal melanoma after treatment with proton beam irradiation or enucleation. American Journal of Ophthalmology 1985;99(3):282–90. | 2983558
Seddon JM, Gragoudas ES, Egan KM, et al. Relative survival rates after alternative therapies for uveal melanoma. Ophthalmology 1990;97(6):769–77. | 2374681
Seddon JM, Gragoudas ES, Egan KM, et al. Uveal melanomas near the optic disc or fovea. Visual results after proton beam irradiation. Ophthalmology 1987;94(4):354–61. | 3587916
Seddon JM, Gragoudas ES, Polivogianis L, et al. Visual outcome after proton beam irradiation of uveal melanoma. Ophthalmology 1986;93(5):666–74. | 3014415
Spatola C, Privitera G, Raffaele L, et al. Clinical application of proton beams in the treatment of uveal melanoma: the first therapies carried out in Italy and preliminary results (CATANA Project). Tumori 2003 Oct;89(5):502–9. | 14870772
Tsina EK, Lane AM, Zacks DN, et al. Treatment of metastatic tumors of the choroid with proton beam irradiation. Ophthalmology 2005;112(2):337–43. | 15691572
Tsuji H, Ishikawa H, Yanagi T, et al. Carbon-ion radiotherapy for locally advanced or unfavorably located choroidal melanoma: a Phase I/II dose-escalation study. International Journal of Radiation Oncology, Biology, Physics 2007;67(3):857–62. | 17161555
Vitale V, Scolaro T, Andreucci L, et al. [The proton radiotherapy of melanoma of the uvea. The technic, methodology and first clinical observations] [Italian]. Radiologia Medica 1992;84(5):630–5. | 1335591
Wilkes SR, Gragoudas ES. Regression patterns of uveal melanomas after proton beam irradiation. Ophthalmology 1982;89(7):840–4. | 6289219
Wilson MW, Hungerford JL. Comparison of episcleral plaque and proton beam radiation therapy for the treatment of choroidal melanoma. Ophthalmology 1999;106(8):1579–87. | 10442907
Wuestemeyer H, Sauerwein W, Meller D, et al. Proton radiotherapy as an alternative to exenteration in the management of extended conjunctival melanoma. Graefes Archive for Clinical & Experimental Ophthalmology 2006;244(4):438–46. | 16133022
Zografos L, Gailloud C, Perret C, et al. [Report on the conservative treatment of melanoma of the uvea at the Lausanne University Ophthalmologic Clinic] [French]. Klinische Monatsblatter fur Augenheilkunde 192:572–578. | 3404968
Other
Arimoto T, Maruhashi N, Takada Y, et al. Acute skin reactions observed in fractionated proton irradiation. Radiation Medicine 1989;7(1):23–7. | 2548232
Austin-Seymour M, Munzenrider JE, Goitein M, et al. Progress in low-LET heavy particle therapy: intracranial and paracranial tumors and uveal melanomas. Radiation Research 1985;(Supplement 8):S219–26. | 3003784
Castro JR, Saunders WM, Tobias CA, et al. Treatment of cancer with heavy charged particles. International Journal of Radiation Oncology, Biology, Physics 1982;8(12 ):2191–8. | 6819279
Ishikawa H, Tsuji H, Tsujii H. [Clinical experience of carbon ion radiotherapy for malignant tumors] [review] [13 refs] [Japanese]. Gan to Kagaku Ryoho [Japanese Journal of Cancer & Chemotherapy] 2006;33(4):444–9. | 16612151
Kagei K, Tokuuye K, Sugahara S, et al. [Initial experience of proton beam therapy at the new facility of the University of Tsukuba] [Japanese]. Nippon Igaku Hoshasen Gakkai Zasshi - Nippon Acta Radiologica 2004;64(4):225–30. | 15211886
Kitagawa T. [Proton beam therapy of cancer in deep-seated organs] [Japanese]. Gan No Rinsho - Japanese Journal of Cancer Clinics 1988;34(13):1839–44. | 2848958
Kitagawa T, Inada T, Arimoto T et al. [Clinical investigation of indications in proton therapy] [Japanese]. Gan No Rinsho - Japanese Journal of Cancer Clinics 1986;32(7):729–39. | 3016360
Linstadt DE, Castro JR, Phillips TL. Neon ion radiotherapy: results of the phase I/II clinical trial. International Journal of Radiation Oncology, Biology, Physics 1991;20:761–769. | 2004953
Munzenrider JE, ustin-Seymour M, Blitzer PJ, et al. Proton therapy at Harvard. Strahlentherapie 1985;161(12 ):756–63. | 3001976
Murayama S, Fuji H, Yamashita H, et al. [Initial clinical experience of proton therapy at Shizuoka Cancer Center] [Japanese]. Nippon Igaku Hoshasen Gakkai Zasshi - Nippon Acta Radiologica 2005;65(4):424–31. | 16334397
Saunders W, Castro JR, Chen GT, et al. Helium-ion radiation therapy at the Lawrence Berkeley Laboratory: recent results of a Northern California Oncology Group Clinical Trial. Radiation Research 1985;(Supplement 8):S227–34. | 3937171
Suit H, Goitein M, Munzenrider J, et al. Evaluation of the clinical applicability of proton beams in definitive fractionated radiation therapy. International Journal of Radiation Oncology, Biology, Physics 1982;8(12):2199–205. | 6298160
Tsujii H, Tsuji H, Inada T, et al. Clinical results of fractionated proton therapy. International Journal of Radiation Oncology, Biology, Physics 1993;25(1):49–60. | 8380147
Umebayashi Y, Uyeno K, Tsujii H, et al. Proton radiotherapy of skin carcinomas. British Journal of Dermatology 1994;130(1):88–91. | 8305324
Prostate
Akakura K, Tsujii H, Morita S, et al. Phase I/II clinical trials of carbon ion therapy for prostate cancer [erratum appears in Prostate 2004 Sep 15;61(1):103]. Prostate 2004;58(3):252–8. | 14743464
Benk VA, Adams JA, Shipley WU, et al. Late rectal bleeding following combined X-ray and proton high dose irradiation for patients with stages T3-T4 prostate carcinoma. International Journal of Radiation Oncology, Biology, Physics 1993;26(3):551–7. | 8514551
Duttenhaver JR, Shipley WU, Perrone T, et al. Protons or megavoltage X-rays as boost therapy for patients irradiated for localized prostatic carcinoma. An early phase I/II comparison. Cancer 1983;51(9):1599–604. | 6299503
Galbraith ME, Ramirez JM, Pedro LW. Quality of life, health outcomes, and identity for patients with prostate cancer in five different treatment groups. Oncology Nursing Forum 22001;8(3):551–60. | 11338762
Gardner BG, Zietman AL, Shipley WU, et al. Late normal tissue sequelae in the second decade after high dose radiation therapy with combined photons and conformal protons for locally advanced prostate cancer. Journal of Urology 2002;167(1):123–6. | 11743288
Hara I, Murakami M, Kagawa K, et al. Experience with conformal proton therapy for early prostate cancer. American Journal of Clinical Oncology 2004;27(4):323–7. | 15289722
Ishikawa H, Tsuji H, Kamada T, et al. Carbon ion radiation therapy for prostate cancer: results of a prospective phase II study. Radiotherapy & Oncology 2006;81(1):57–64. | 16971008
Ishikawa H, Tsuji H, Kamada T, et al. Risk factors of late rectal bleeding after carbon ion therapy for prostate cancer. International Journal of Radiation Oncology, Biology, Physics 2006;66(4):1084–91. | 16979840
Mayahara H, Murakami M, Kagawa K, et al. Acute morbidity of proton therapy for prostate cancer: the Hyogo Ion Beam Medical Center experience. International Journal of Radiation Oncology, Biology, Physics 2007;69(2):434–43. | 17482768
Nihei K, Ogino T, Ishikura S, et al. Phase II feasibility study of high-dose radiotherapy for prostate cancer using proton boost therapy: first clinical trial of proton beam therapy for prostate cancer in Japan. Japanese Journal of Clinical Oncology 2005;35(12):745–52. | 16314345
Rossi Jr CJ, Slater JD, Yonemoto LT, et al. Influence of patient age on biochemical freedom from disease in patients undergoing conformal proton radiotherapy of organ-confined prostate cancer. Urology 2004;64(4):729–32. | 15491710
Schulte RW, Slater JD, Rossi Jr CJ, et al. Value and perspectives of proton radiation therapy for limited stage prostate cancer. Strahlentherapie und Onkologie 200;176(1):3–8. | 10650829
Shipley WU, Tepper JE, Prout Jr GR, et al. Proton radiation as boost therapy for localized prostatic carcinoma. JAMA 1979;241(18 ):1912–5. | 107338
Shipley WU, Verhey LJ, Munzenrider JE, et al. Advanced prostate cancer: the results of a randomized comparative trial of high dose irradiation boosting with conformal protons compared with conventional dose irradiation using photons alone [see comment]. International Journal of Radiation Oncology, Biology, Physics 1995;32(1):3–12. | 7721636
Slater JD, Yonemoto LT, Rossi Jr CJ, et al. Conformal proton therapy for prostate carcinoma. International Journal of Radiation Oncology, Biology, Physics 1998;42(2):299–304. | 9788407
Slater JD, Rossi Jr CJ, Yonemoto LT, et al. Conformal proton therapy for early-stage prostate cancer. Urology 1999;53(5):978–84. | 10223493
Slater JD, Rossi Jr CJ, Yonemoto LT, et al. Proton therapy for prostate cancer: the initial Loma Linda University experience. International Journal of Radiation Oncology, Biology, Physics 2004;59(2):348–52. | 15145147
Tsuji H, Yanagi T, Ishikawa H, et al. Hypofractionated radiotherapy with carbon ion beams for prostate cancer. International Journal of Radiation Oncology, Biology, Physics 2005;63(4):1153–60. | 15990247
Zietman AL, DeSilvio ML, Slater JD, et al. Comparison of conventional-dose vs high-dose conformal radiation therapy in clinically localized adenocarcinoma of the prostate: a randomized controlled trial [see comment]. JAMA 2005;294(10):1233–9. | 16160131
Spine
Castro JR, Collier JM, Petti PL, et al. Charged particle radiotherapy for lesions encircling the brain stem or spinal cord. International Journal of Radiation Oncology, Biology, Physics 1989;17(3):477–84. | 2506156
Fitzek MM, Thornton AF, Rabinov JD, et al. Accelerated fractionated proton/photon irradiation to 90 cobalt gray equivalent for glioblastoma multiforme: results of a phase II prospective trial. Journal of Neurosurgery 1999;91(2):251–60. | 10433313
Hug EB, Fitzek MM, Liebsch NJ, et al. Locally challenging osteo- and chondrogenic tumors of the axial skeleton: results of combined proton and photon radiation therapy using three- dimensional treatment planning. International Journal of Radiation Oncology, Biology, Physics 1995;31(3):467–76. | 7852108
Imai R, Kamada T, Tsuji H, et al. Carbon ion radiotherapy for unresectable sacral chordomas. Clinical Cancer Research 2004;10(17):5741–6. | 15355901
Marucci L, Niemierko A, Liebsch NJ, et al. Spinal cord tolerance to high-dose fractionated 3D conformal proton-photon irradiation as evaluated by equivalent uniform dose and dose volume histogram analysis. International Journal of Radiation Oncology, Biology, Physics 2004;59(2):551–5. | 15145175
Nowakowski VA, Castro JR, Petti PL, et al. Charged particle radiotherapy of paraspinal tumors. International Journal of Radiation Oncology, Biology, Physics 1992;22(2):295–303. | 1740393
Park L, Delaney TF, Liebsch NJ, et al. Sacral chordomas: Impact of high-dose proton/photon- beam radiation therapy combined with or without surgery for primary versus recurrent tumor. International Journal of Radiation Oncology, Biology, Physics 2006;65(5):1514–21. | 16757128
Rutz HP, Weber DC, Sugahara S, et al. Extracranial chordoma: Outcome in patients treated with function-preserving surgery followed by spot-scanning proton beam irradiation. International Journal of Radiation Oncology, Biology, Physics 2007;67(2):512–20. | 17084540
Schoenthaler R, Castro JR, Petti PL, et al. Charged particle irradiation of sacral chordomas. International Journal of Radiation Oncology, Biology, Physics 1993;26(2):291–8. | 8491686
Uterus (cervix and corpus)
Arimoto T, Kitagawa T, Tsujii H, et al. High-energy proton beam radiation therapy for gynecologic malignancies. Potential of proton beam as an alternative to brachytherapy. Cancer 1991;68(1):79–83. | 1904794
Kagei K, Tokuuye K, Okumura T, et al. Long-term results of proton beam therapy for carcinoma of the uterine cervix. International Journal of Radiation Oncology, Biology, Physics 2003;55(5):1265–71. | 12654436
Kato S, Ohno T, Tsujii H, et al. Dose escalation study of carbon ion radiotherapy for locally advanced carcinoma of the uterine cervix. International Journal of Radiation Oncology, Biology, Physics 2006;65(2):388–97. | 16626894
Nakano T, Suzuki M, Abe A, et al. The phase I/II clinical study of carbon ion therapy for cancer of the uterine cervix. Cancer Journal From Scientific American 1999;5(6):362–9. | 10606478
Nakano T, Suzuki Y, Ohno T, et al. Carbon beam therapy overcomes the radiation resistance of uterine cervical cancer originating from hypoxia. Clinical Cancer Research 2006;12(7 Pt 1):2185–90. | 16609033