# Ovid Medline Search Strategy

ID | Search term | Citations
1 | particle beam.mp. | 157
2 | heavy ion*.mp. or exp Heavy Ions/ | 1411
3 | light ion*.mp. | 115
4 | charged particle*.mp. | 1114
5 | boron neutron captrure.mp. | 0
6 | hadron$.mp. | 168
7 | proton$.mp. or exp Protons/ | 70128
8 | Carbon ion.mp. | 225
9 | C-ion$.mp. | 152
10 | helium ion$.mp. | 202
11 | He-ion$.mp. | 26
12 | exp Alpha Particles/or alpha irradiation.mp. | 1872
13 | (LET or linear energy transfer).mp. | 12772
14 | exp Particle Accelerators/ | 5736
15 | or/1–14 | 90173
16 | exp Radiotherapy/ | 98150
17 | exp Radiotherapy, High-Energy/ | 14620
18 | irradiation.mp. or exp Pituitary Irradiation/or exp Lymphatic Irradiation/or exp Cranial Irradiation/ | 107651
19 | beam therap*.mp. | 1047
20 | pion* therap*.mp. | 29
21 | piontherap*.mp. | 0
22 | proton* therap*.mp. | 380
23 | protontherap*.mp. | 55
24 | neutron capture therap*.mp. | 1288
25 | neutron therap*.mp. | 551
26 | neutrontherap*.mp. | 12
27 | ion$ therap*.mp. | 152
28 | iontherap*.mp. | 2
29 | beam irradiation.mp. | 1806
30 | beam radiation.mp. | 2485
31 | radiation therap*.mp. | 34480
32 | particle therap*.mp. | 111
33 | hadron$therap*.mp. | 39
34 | hadrontherap*.mp. | 39
35 | particle beam therap*.mp. | 10
36 | charged particle therap*.mp. | 47
37 | or/16–36 | 195909
38 | 15 and 37 | 7458
39 | limit 38 to humans | 4776
40 | remove duplicates from 39 | 4747