# Selected Internet Links

Appendix Table A1 Internet links for radiotherapy organizations

Organization | URL address
Deutsche Gesellschaft fur Radiooncologie | http://www.degro.org/jsp_public/cms/index.jsp
European Society for Therapeutic Radiology and Oncology | http://www.estroweb.org/estro/index.cfm
American Society for Therapeutic Radiology and Oncology | http://www.astro.org/
National Association for Proton Therapy | http://www.proton-therapy.org/
Particle Therapy Cooperative Group | http://ptcog.web.psi.ch/

(Accessed June 16, 2008)

Appendix Table A2 Internet links for particle beam instrumentation companies

Company | URL address
Ion Beam Applications (IBA) Solutions | http://www.iba-worldwide.com/
Still River Systems Inc | http://www.stillriversystems.com/
Optivus Proton Therapy | http://www.optivus.com/
Siemens | http://www.medical.siemens.com/
Hitachi: Proton beam Therapy | http://www.pi.hitachi.co.jp/rd-eng/product/industrial-sys/accelerator-sys/proton-therapy-sys/proton-beam-therapy/index.html
ACCEL Instruments | http://www.proton-therapy.com/

(Accessed June 16, 2008)

Appendix Table A3 Internet links for particle beam treatment centers in the USA

Center/Institute | URL address
Francis H. Burr Proton Therapy Center (NPTC) | http://www.massgeneral.org/cancer/about/providers/radiation/proton/index.asp
Loma Linda University Proton Therapy Center | http://www.llu.edu/proton/index.html
University of California, Crocker Nuclear Lab | http://media.cnl.ucdavis.edu/crocker/website/default.php
Midwest Proton Radiotherapy Institute, Bloomington | http://www.mpri.org/
M.D. Anderson Proton Therapy Center, Houston | http://www.mdanderson.org/care_centers/radiationonco/ptc/
University of Florida Proton Therapy Institute, Jacksonville | http://www.floridaproton.org/

(Accessed June 16, 2008)