# Results

The search strategy yielded 250 articles. The selection process is described below:

The 96 included reports comprised 62 full reports and 34 abstract-only publications. Each report and the sections within this review in which they fell (i.e., efficacy, adverse effects, predictors) is reviewed in the Included Studies table.

There were a total of 69 studies that presented some efficacy findings. Among these, study designs included 7 phase III controlled clinical trials and 62 phase II trials. Of the phase III trials, two were published as full text articles. Neither presented unblinded results. The five remaining phase III trials were published in abstract form only.

Quality of the studies was generally poor (Appendix B and Tables 1a, 1b and 1c). Less than half of studies achieved a threshold quality score of 4/6. Quality was poor across all study types―efficacy, adverse effects, and predictors. The large volume of abstracts that could not be assessed from a quality standpoint made overall quality even more concerning.

A review of all studies included in this report, including phase, thalidomide dose, comparator, size, and quality is presented in Table 1. Efficacy studies are broken down into category corresponding to thalidomide drug combinations and presence or absence of prior myeloma therapies (see Figure 10; Tables 2–8). Adverse effect tables are presented according to those that match studies presented in the efficacy tables (Table 9) and independent studies representing adverse effect findings (Table 10). Predictors are organized by mechanism of action (Table 11), demographic factors (Table 12) clinical predictors (Table 13), and predictors related to thalidomide dosage or response (Table 14).

Table 1a Details of included studies –Thalidomide efficacy studies (corresponding to Tables 2–8)

First Author, Year | Trial Phase | Thal dose per day (mg) | Comparator | N | Quality | Comments
Thalidomide only–newly diagnosed/previously untreated multiple myeloma (TABLE 2)
Rajkumar, 2001^41^ | II | 200–800 | | 16 | 4/5 | Asymptomatic SMM or IMM
Rajkumar, 2003^42^ | II | 50–800 | | 29 | 3/5 | Asymptomatic SMM or IMM
Total # studies in category: 2 Total abstracts (*): 0 | Total # Phase III: 0 | | | Total N: 45 | Total with quality 4/6: 1 of 2 (50%)
Thalidomide only–advanced/refractory/resistant multiple myeloma (TABLE 3)
Barlogie, 2001^43^ | II | 200–800 | | 169 | 4/6
Corso, 2002^44^ | II | 200 | CAVD chemo | 21 | 0/5
Hattori, 2004^45^ | II | 200–400 | | 44 | 4/5
Hus, 2001^46^ | II | 200–400 | Historical control | 53 | 3/6 | Also with hypocellular BM, pancytopenia
Johnston, 2002^47^ | II | 50–500 | | 12 | 3/5
Juliusson, 2000^48^ | II | 200–800 | | 23 | 1/5
Kees, 2003^49^ | II | 50–400 | Thal/Dex Thal/VAD | 24 | 2/6
*Kroeger, 2004 (ASH 1646)50 | II | 100–300 | | 18 | * | Prior to donor lymphocyte infusion
Kumar, 2003^51^ | II | 200–800 | | 32 | 4/5
Neben, Moehler, Egerer et al. 2001^52^ | II | 100–400 | | 54 | 3/6
Rajkumar, 2000^53^ | II | 200–800 | | 16 | 3/5
Richardson, 2004^54^ | II | 200–600 | | 26 | 3/5
Schey, 2003^55^ | II | 100–600 | | 69 | 4/5
Singhal, 1999^35^ | II | 200–800 | | 84 | 5/5
Tosi, 2001^56^ | II | 100–800 | | 11 | 3/5
Tosi, 2002 57 | II | 100–800 | | 60 | 2/5
Waage, 2004^58^ | II | 200–800 | | 65 | 4/5
Yakoub-Agha, 2000^59^ | II | 100–800 | | 27 | 4/5
Yakoub-Agha, 2002^60^ | II | 50–800 | | 83 | 6/6
Total # studies in category: 19 Total abstracts (*): 1 | Total # Phase III: 0 | | | Total N: 891 | Total with quality 4/6: 8 of 18 (44%)
Thalidomide plus dexamethasone–newly diagnosed/previously untreated multiple myeloma (TABLE 4)
*Rajkumar, 2004 (ASH 205)61; *Rajkumar, 2004 (ASCO 6508)62 | III | 200 | Dex | 198 | * | RCT of Thal/Dex vs. Dex
*Ludwig, 2005 (ASCO 6537)63 | III | 200 | MP | 137 | * | RCT of Thal/dex vs. MP for elderly pts; not completed enrollment;
Alexanian, 2003^64^ | II | 100–400 | | NS | 1/6
Rajkumar, 2002 65 | II | 50–200 | | 50 | 4/5
*Rajkumar, 2005 (ASCO 6632)66 | II | 200 | | 24 | *
Weber, 2003^67^ | II | 100–600 | Thal | 68 | 3/6 | Included pts that received thal alone
Total # studies in category: 6 Total abstracts (*): 4 | Total # Phase III: 2 | | | Total N: 477+ | | Total with quality 4/6: 1 of 3 (33%)
Thalidomide plus dexamethasone–advanced/refractory/resistant multiple Myeloma (TABLE 5)
Alexanian, 2003^64^ | II | 200–800 | | 43 | 1/6 | Mixed clinical settings
Alexanian, 2003^64^; Anagnotopoulos, 2003^68^ | II | 200–600 | | 47 | 1/6 1/6 | 2 reports that combine data
Bernardeschi, 2004^69^ | II | 100–400 | | 20 | 2/5
Dimopoulos, 2001^70^ | II | 200–400 | | 44 | 3/5
Myers, 2000^71^; | II | 50–400 | | 27 | 2/5 | 3 reports about same group of pts
Myers, 2001^72^; Myers, 2002^73^ Palumbo, 2001^74^ | II | 100 | | 77 | 2/5
Palumbo, 2004^75^ | II | 50–100 | Historical control | 120 | 6/6
*Reece, 2004 (ASH 4934)76 | II | 50–400 | Thal vs. Thal/dex | 29 | * | Thal/dex could have been thal/dex or thal/prednisone
Tosi, 2004 (ASH 4898)77 | II | 100–400 | | 20 | 4/5 | All with renal failure
Total # studies in category: 9 Total abstracts (*): 1 | Total # Phase III: 0 | | | Total N: 427 | Total with quality 4/6: 2 of 9 (22%)
Thalidomide plus other agents–newly diagnosed/previously untreated multiple myeloma (TABLE 6)
*Facon, 2004 (ASH 206)78 | III | 400 | See comment | 200 | * | RCT of MP vs. MP-thal, vs. high dose melphalan + VAD + SCT; not completed enrollment; age 75 yrs
*Palumbo, 2004 (ASH 207)79 | III | 100 | MP | 102 | * | RCT of MP vs. MP-thal
*Alexanian, 2004 (ASH 210)80 | II | 100–200 | | 25 | * | Bortezomib + doxorubicin + thal + dex
*Chanan-Khan, Miller, McCarthy, Koryzna et al., 2004 (ASH 3463)81 | II | 100–200 | | 11 | * | VAD + thal
*Dimopoulos, 2004 (ASH 1482)82 | II | 300 | | 43 | * | Melphalan + dex + thal; not completed enrollment; age 75 yrs
*Hassoun, 2004 (ASH 2409)83 | II | 200 | | 30 | * | Doxorubicin + dex followed by thal/dex
*Klueppelberg, 2004 (ASH 4932)84; *Klueppelberg, 2004 (ASCO 6702)85; *Klueppelberg, 2005 (ASCO 6697)86 | II | 100 | | 29 | * | Thal + dex + zoledronate; 14% HIV+; 3 reports of ongoing study with increasing enrollment
Schutt, 2005^87^ | II | 200–400 | | 31 | 5/5 | Thal + vincristine + epirubicin + dex
Zervas, 2004^88^ | II | 200 | | 39 | 3/5 | Thal + VAD + extra dex
Total # studies in category: 9 Total abstracts (*): 9 | Total # Phase III: 2 | | | Total N: 510 | Total with quality 4/6: 1 of 2 (50%)
Thalidomide plus other agents–advanced/refractory/resistant multiple myeloma (TABLE 7)
*Badros, 2004 (ASH 2400)89 | II | 100–400 | | 30 | * | Oblimerson + dex + thal
*Bibas, 2004 (ASH 4927)90 | II | 100+ | | 30 | * | Thal + dex + zoledronate
*Chanan-Khan, Miller, McCarthy, DiMiceli et al. 2004 (ASH 2421)91 | II | 200 | | 13 | * | Bortezomib + liposomal doxorubicin + thal
Biagi, 2001^92^ | II | 200–800 | | 4 | 1/6 | Thal + interferon
Ciepluch, 2002^93^ | II | 200–400 | | 13 | 1/5 | Thal + pamidronate
Dimopoulos, 2004^94^ | II | 400 | | 53 | 3/5 | Cyclophosphamide po + thal + dex
Garcia-Sanz, 2004^95^ | II | 200–800 | | 66 | 4/5 | Cyclophosphamide po + thal + dex
*Hollmig, 2004 (ASH 2399)96 | II | 50–100 | | 14 | * | Bortezomib + doxorubicin + thal + dex
Kasper, 2004^97^ | II | 100–400 | | 15 | 2/5 | Thal + pegylated interferon
Kropff, 2003^98^ | II | 100–400 | | 57 | 5/5 | Thal + dex + iv cyclophosphamide
Mileshkin, Biagi et al. 2003^99^ | II | 200–1000 | | 75 | 5/6 | Thal +/− interferon
*Mileshkin, 2005 (ASCO 8233)100 | II | Up to 800 | | 66 | * | Thal + celecoxib; QOL outcomes
Offidani, Corvatta, Marconi, Malerba, et al. 2004 101 | II | 100–400 | | 59 | 0/6 | Thal +/− melphalan
Offidani, Corvatta, Marconi, Olivieri, et al. 2004^102^ | II | 100–600 | | 50 | 6/6 | Thal +/− melphalan
*Suvannasankha, 2005 (ASCO 6591)103 | II | 200 | | 37 | * | Thal + po cyclophosphamide + prednisone
*Teoh, 2004 (ASH 4915)104 | II | 50 | | 18 | * | Thal + dex + zoledronate
*Williams, 2004 (ASH 1499)105, 106 | II | 100–200 | | 62 | * | Thal + dex + po cyclophosphamide; includes 24% newly diagnosed pts
*Zangari, Barlogie, Hollmig, et al. 2004 (ASH 1480)107 | II | 50–200 | Bortezomib | 79 | * | Bortezomib + thal
Total # studies in category: 18 Total abstracts (*): 9 | Total # Phase III: 0 | | | Total N: 741 | Total with quality 4/6: 4 of 9 (44%)
Thalidomide used as part of the pre or post stem cell transplantation regimen (TABLE 8)
*Attal, 2004 (ASH 535)108 | III | NS | See comments | 580 | * | Thal for post-SCT maintenance: randomized btwn no maintenance, pamidronate, pamidronate + thal
Barlogie, 2002^109^ *Barlogie, 2004 (ASH 1483)110 | III | 400 | No thal | 231 104 | 2/6 * | Randomized to thal vs. no thal at beginning of Total Therapy II program; not completed enrollment; doesn’t present unblinded outcomes Second report of trial; 104 of 668 randomized pts to thal vs. no thal; follow up report
Lee, 2003^21^ | III | 50–400 | See comments | 236 | 4/5 | DTPACE × 2 then if response randomized to SCT vs. DTPACE × 4; report is for only first 2 cycles of DTPACE
Alexanian, 2002^111^; Alexanian, 2003^64^ | II | 100–300 | 21 | | 2/5 1/6 | 2 reports that combine data
*Sengar, 2005 (ASCO 6731)112 | II? | 50 | | 17 | * | Randomized btwn maintenance thal or interferon after SCT; unclear if Phase II or III; no unblinded data presented
*Stewart, 2004 (ASH 335)113 | II | 200–400 | | 67 | * | Thal + prednisone for post-SCT maintenance; randomized btwn thal 200 mg and 400 mg
Total # studies in category: 6 Total abstracts (*): 4 | Total # Phase III: 3 | | | Total N: 1152 | Total with quality 4/6: 1 of 4 (25%)

* Presented as peer-reviewed abstract only.

Abbreviations: autoSCT = autologous stem cell transplantation; BM = bone marrow; btwn = between; CAVD = lomustine + melphalan + etoposide + dexamethasone; chemo = chemotherapy; Dex = dexamethasone; DTPACE: Dex + thal + cisplatin + doxorubicin, cyclophosphamide + etoposide; HIV = human immunodeficiency virus; IMM = indolent multiple myeloma; iv = intravenous; MP = melphalan po + prednisone; N = number; NS = not stated; po = oral; pt(s) = patient(s); QOL = quality of life; RCT = randomized controlled trial; SCT = stem cell transplantation; SMM = smoldering multiple myeloma; Thal = thalidomide; VAD = vincristine + doxorubicin + dexamethasone; vs. = versus; yrs = years

Table 1b Details of included studies –Articles focusing on adverse effects due to thalidomide corresponding to Table 10 (in addition to adverse events information reported in efficacy studies and presented in Table 9)

First Author, Year | Thal dose per day (mg) | Comparator | N | Quality | Adverse event
*Anaissie, 2004 (ASH 3467)114 | NS | | 553 | * | Avascular necrosis
Badros, 2002^115^ | 200–800 | w/ or w/o chemo | 174 | 2/5 | Subclinical hypothyroidism
Bowcock, 2002^116^ | 150 | Historical control | 41 | 0/5 | Thromboembolism
Fahdi, 2004^117^ | 200 | Placebo | | 4/6 | Bradycardia
Hall, 2003^118^ | 200–800 | Thal and thal/dex | 77 | 1/5 | Dermatological reactions
Hattori, 2004^45^ | 200–400 | | 44 | 4/5 | Cytopenias
*Singh, 2004 (ASCO 3142)119 | NS | | 257 | * | Thromboembolism
*Spencer, 2004 (ASCO 6655)120 | 200 | | 83 | * | Renal function
*Tosi, 2004 (ASH 4898)77 | 200 | New dx vs. pretreated | 74 | * | Neurotoxicity
Tosi, 2005^121^ | 200–400 | | 40 | 4/6 | Late toxicity after 1 yr of thal; Neurotoxicity
Zangari, 2001^122^ | 400 | Thal vs. no thal | 100 | 0/5 | Thromboembolism
Zangari, Saghafifar, et al. 2002^123^ | 400 | Thal vs. no thal | 62 | 0/6 | Thromboembolism
Zangari, Siegel, et al. 2002^124^ | 400 | Thal + doxorubicin or no doxorubicin (DTPACE) | 232 | 2/6 | Thromboembolism
*Zangari, Barlogie, Lee, et al 2004 (ASH 4914)125 | NS | Thal + bortezomib or no bortezomib (VDTPACE) | 24 | * | Thromboembolism
Zangari, 2004^126^ | 400 | DVT prophylaxis vs. none | 386 | 6/6 | Thromboembolism prophylaxis
Total # studies in category: 15 Total abstracts (*): 5 | | | Total N: 45 | Total with quality 4/6: 4 of 10 (40%)

* Presented as peer-reviewed abstract only.

Abbreviations: chemo = chemotherapy; Dex = dexamethasone; DTPACE: Dex + thal + cisplatin + doxorubicin, cyclophosphamide + etoposide; N = number; NS = not stated; Thal = thalidomide; V = bortezomib; vs. = versus; w/ = with; w/o = without

Table 1c Details of included studies–Articles with information on predictors of response to thalidomide corresponding to Tables 11–14

First Author, Year | Treatment | N | Quality | Predictor
Predictors related to the potential mechanism of thalidomide action (TABLE 11)
Singhal, 1999 {Singhal, #592} | Thal only | 84 | 5/5 | BM Microvascular Density
Mileshkin, Prince, et al., 2003^127^ | | 75 | 4/6 | Serum mucin-1 (sMUC-1)
Dmoszynska, 2002^128^ | | 30 | 3/5 | Fibroblast Growth Factor (FGF)
Neben, Moehler, Egerer et al. 2001^52^ | Thal only | 54 | 3/6 | Fibroblast Growth Factor (FGF)
Neben, Moehler, Kraemer et al. 2001^129^ | | 51 | 3/6 | Fibroblast Growth Factor (FGF)
Tosi, 2002 57 | Thal only | 65 | 2/5 | Fibroblast Growth Factor (FGF)
Neben, Moehler, Kraemer et al. 2001^129^ | | 51 | 3/6 | Hepatocyte growth factor (HGF)
Dmoszynska, 2002^128^ | | 30 | 35 | Interleukin-6 (IL-6)
Neben, Moehler, Kraemer et al. 2001^129^ | | 51 | 3/6 | Interleukin-6 (IL-6)
Thompson, 2003^130^ | | 38 | 1/5 | Interleukin-6 (IL-6)
Dmoszynska, 2002^128^ | | 30 | 3/6 | Tumor necrosis factor alpha (TNFα )
Neben, Moehler, Kraemer et al. 2001^129^ | | 51 | 3/6 | Tumor necrosis factor alpha (TNFα )
Thompson, 2003^130^ | | 38 | 1/5 | Tumor necrosis factor alpha (TNFα )
Neben, Mytilineos, et al., 2002^131^ | | 81 | 3/6 | TNFα polymorphisms at position -238 of the gene promoter
Neben, Mytilineos, et al., 2002^131^ | | 81 | 3/6 | TNFα polymorphisms at position -308 of the gene promoter
*Jaksic, 2004 (ASH 2417)132 | | 16 | * | t(4;14) positive multiple myeloma
Dmoszynska, 2002^128^ | | 30 | 3/5 | Vascular Endothelial Growth Factor (VEGF)
Neben, Moehler, Egerer et al. 2001^52^ | Thal only | 54 | 3/6 | Vascular Endothelial Growth Factor (VEGF)
Neben, Moehler, Kraemer et al. 2001^129^ | | 51 | 3/6 | Vascular Endothelial Growth Factor (VEGF)
Tosi, 2002 57 | Thal only | 65 | 2/5 | Vascular Endothelial Growth Factor (VEGF)
Total # studies in category: 9 Total abstracts (*): 1 | | | | Total predictors in category studied: 10
Predictors related to patient demographic factors (TABLE 12)
Barlogie, 2002^109^ | Thal + other | 231 | 4/6 | Age
Mileshkin, Biagi, et al. 2003^99^ | Thal + other | 75 | 5/6 | Age
Shaughnessy, 2003^133^ | | 231 | 2/6 | Age
Yakoub-Agha, 2002^60^ | Thal only | 83 | 6/6 | Age
Dimopoulos, 2004^94^ | Thal + other | 53 | 3/5 | Gender
Dimopoulos, 2001^70^ | Thal + Dex | 44 | 3/5 | Performance status (ECOG)
Dimopoulos, 2004^94^ | Thal + other | 53 | 3/5 | Performance status (ECOG)
Singhal, 1999^35^ | Thal only | 84 | 5/5 | % of plasma cells in BM
Garcia-Sanz, 2004^95^ | Thal + other | 66 | 4/5 | Relapsed versus refractory disease
Yakoub-Agha, 2002^60^ | Thal only | 83 | 6/6 | Time from diagnosis to onset of Thal
Total # studies in category: 8 Total abstracts (*): 0 | | | | Total predictors in category studied: 6
Predictors related to clinical diagnostic test results (TABLE 13)
Barlogie, 2001^43^ | Thal only | 169 | 4/6 | Cytogenetics
Shaughnessy, 2003^133^ | | 231 | 2/6 | Cytogenetics
Barlogie, 2002^109^ | Thal + other | 231 | 2/5 | Chromosome 13 abnormality
Mileshkin, Biagi, et al. 2003^99^ | Thal + other | 75 | 2/6 | Chromosome 13 abnormality
Shaughnessy, 2003^133^ | | 231 | 2/6 | Chromosome 13 abnormality
Singhal, 1999^35^ | Thal only | 84 | 5/5 | Chromosome 13 abnormality
*Attal, 2004 (ASH 535)108 | Thal + other | 580 | * | Chromosome 13 abnormality
Dimopoulos, 2004^94^ | Thal + other | 53 | 3/5 | Albumin
Shaughnessy, 2003^133^ | | 231 | 2/6 | Albumin
Singhal, 1999^35^ | Thal only | 84 | 5/5 | Albumin
Yakoub-Agha, 2002^60^ | Thal only | 83 | 6/6 | Albumin
Garcia-Sanz, 2004^95^ | Thal + other | 66 | 4/5 | Beta 2 microglobulin (B2M)
Mileshkin, Biagi, et al. 2003^99^ | Thal + other | 75 | 5/6 | Beta 2 microglobulin (B2M)
Neben, Moehler, Egerer et al. 2001^52^ | Thal only | 54 | 3/6 | Beta 2 microglobulin (B2M)M
Shaughnessy, 2003^133^ | | 231 | 2/6 | Beta 2 microglobulin (B2M)
Schutt, 2005^87^ | Thal + other | 31 | 5/5 | Beta 2 microglobulin (B2M)
*Attal, 2004 (ASH 535)108 | Thal + other | 580 | * | Beta 2 microglobulin (B2M)
Dimopoulos, 2001^70^ | | 44 | 3/5 | Hemoglobin
Mileshkin, Biagi, et al. 2003^99^ | Thal + other | 75 | 3/6 | Hemoglobin
Neben, Moehler, Egerer et al. 2001^52^ | | 54 | 3/6 | Hemoglobin
Garcia-Sanz, 2004^95^ | Thal + other | 66 | 4/5 | Platelets
Dimopoulos, 2001^70^ | Thal + Dex | 44 | 3/5 | Serum lactose dehydrogenase (LDH)
Dimopoulos, 2004^94^ | Thal + other | 53 | 3/5 | Serum lactose dehydrogenase (LDH)
Mileshkin, Biagi, et al. 2003^99^ | Thal + other | 75 | 5/6 | Serum lactose dehydrogenase (LDH)
Shaughnessy, 2003^133^ | | 231 | 2/6 | Serum lactose dehydrogenase (LDH)
Singhal, 1999^35^ | Thal + other | 84 | 5/5 | Serum lactose dehydrogenase (LDH)
Shaughnessy, 2003^133^ | | 231 | 2/6 | C Reactive Protein
Singhal, 1999^35^ | Thal + other | 84 | 5/5 | C Reactive Protein
Yakoub-Agha, 2002^60^ | Thal only | 83 | 6/6 | IgA Isotype
Dimopoulos, 2001^70^ | Thal + Dex | 44 | 3/5 | Light chain type
Barlogie, 2001^43^ | Thal only | 169 | 4/6 | Plasma cell labeling index
Singhal, 1999^35^ | Thal only | 84 | 5/5 | Plasma cell labeling index
Total # studies in category: 12 Total abstracts (*): 1 | | | | Total predictors in category studied: 11
Predictors related to Clinical Response to Thalidomide
Neben, Moehler, et al. 2002^134^ | | 83 | 4/6 | Cumulative 3-mo Thal dosage
Yakoub-Agha, 2002^60^ | Thal only | 83 | 6/6 | Cumulative 3-month Thal dosage
Schey, 2003^55^ | Thal only | 69 | 4/5 | Change in paraprotein levels
Singhal, 1999^35^ | Thal only | 84 | 5/5 | Relationship between paraprotein response and BM response
Total # studies in category: 4 Total abstracts (*): 0 | | | | Total predictors in category studied: 3

Abbreviations: B2M = beta 2 microglobulin, BM = bone marrow, Dex = dexamethasone, ECOG = Eastern Cooperative Oncology Group, FGF = Fibroblast Growth Factor, HGF = hepatocyte growth factor, IFN = interferon, PS = performance status, sMUC-1 = serum mucin-1, Thal = Thalidomide, TNF = tumor necrosis factor, VEGF = Vascular Endothelial Growth Factor

## Results

### Part 1. Efficacy

Efficacy is presented in Tables 2–8. The studies naturally segregated into eight groups according to the following figure:

Figure 10 Organization of Thalidomide Efficacy Tables

Table 2 presents two phase II studied of thalidomide only for asymptomatic multiple myeloma. Total number of patients represented is 35. Doses ranged widely from 50–800 mg. Thalidomide achieved CR rates of 16–25 percent and overall paraprotein responses (25 percent) of 66–81 percent, with PPR 50 percent of 34–38 percent. Length of followup was not long enough to allow meaningful comparison to historical survival controls.

Table 3 presents 19 studies with 1 in abstract form. A total of 891 patients with advanced/refractory/resistant multiple myeloma were given thalidomide, in varying doses ranging from 50–800 mg. Thalidomide achieved CR rates of 2–9 percent and overall paraprotein responses (25 percent) of 34–100 percent, with PPR 50 percent of 8–43 percent. The study by Barlogie et al. in 2001 involving 169 participants with advanced refractory myeloma had a median follow up of 22 months.43 Estimated overall survival (OS) at 12 months was 70 percent, and event free survival (EFS) was 25 percent. The estimated 2-year OS was 48 percent +/− 6 percent with 2-year EFS at 20 percent +/− 6 percent. Responses were generally achieved quickly with PPR 50 percent of 30 percent. Of patients achieving PPR 25 percent, 70 percent achieved that response within 2 months and 90 percent within 4.5 months. Similar patterns were seen in other studies. The ideal dose was difficult to determine. Researchers tried to decrease the dose, without clear diminution in effect, however in the Barlogie et al. study higher total doses predicted superior response and survival.43

Table 4 presents six studies of which four are presented in abstract form; two of the abstracts are phase III. Over 447 untreated multiple myeloma patients were given thalidomide in combination with dexamethasone (thal-dex). The thalidomide dose ranged from 50–600 mg. Thalidomide achieved CR rates of 8–16 percent and overall paraprotein responses (25 percent) of 54–92 percent, with PPR 50 percent of 17–64 percent. The Rajkumar et al. study presented in abstract form in 2005 randomized 202 participants to thal-dex versus dex alone.66 Thal-dex rendered higher response rates with 50 percent response rates of 58 percent for thal-dex and 42 percent for dex alone (p=0.0164). The Ludwig et al. study presented in abstract form in 2005^63^ is a randomized controlled trial (RCT) of thal-dex versus oral melphalan and prednisone. Only 137 of a goal 350 participants have been randomized and only 93 were evaluable for this analysis. Overall, thal-dex and melphalan plus prednisone were achieving similar results except for more CRs with thal-dex (13 percent vs. 4 percent) and shorter time to best response with thal-dex (11 weeks vs. 39 weeks). In both of these studies, thalidomide was dosed at 200 mg.

Table 5 presents nine studies of which one is presented in abstract form; none are phase III. A total of 427 advanced/refractory/resistant multiple myeloma patients were given thal-dex. The thalidomide dose ranged from 50–800 mg. Thalidomide achieved CR rates of 0–13 percent and overall paraprotein responses (25 percent) of 54–75 percent, with PPR 50 percent of 22–55 percent. Palumbo and colleagues treated patients with 50–100 mg of thalidomide and monthly pulsed dex.75 The study included 120 patients treated with thal-dex and a group of poorly matched controls who received conventional chemotherapy. Despite its limitations this was the largest and one of the highest quality studies within this group. Patients who received thal-dex were more likely to respond to the intervention and had better overall survival (OS: conventional chemotherapy = 21 mo; thal/dex = 27 mo; p= 0.05). Across this group of studies patients routinely received smaller doses of thalidomide (50–100 mg daily) without any obvious diminution of response.

Table 6 presents nine studies of which seven are presented in abstract form; two are phase III. A total of 510 untreated multiple myeloma patients were given thalidomide with a variety of chemotherapy combinations including oral and parenteral conventional chemotherapy, bisphosphonates, and bortezomib. The thalidomide dose ranged from 100–400 mg. Efficacy results are not summarized into a single numeric range for this group of studies as the interventions are too diverse. Two phase III studies evaluating thalidomide in combination with melphalan are of particular interest. One study has not presented any data yet.78 The study by Palumbo and colleagues identified a substantial improvement in complete response rates when thalidomide was added to standard melphalan and prednisone (CR: 26 percent vs. 4 percent) as well as improved EFS at 26 months (68 percent vs. 32 percent, p<0.001). 79

Table 7 presents 18 studies of which 9 are presented in abstract form; none are phase III. A total of 741 advanced/refractory/resistant multiple myeloma patients were given thalidomide with a variety of chemotherapy combinations including oral and parenteral conventional chemotherapy, bisphosphonates, interferon, and bortezomib. The thalidomide dose ranged from 50–1000 mg. Efficacy results are not summarized into a single numeric range for this group of studies as the interventions are too diverse. The most interesting message across this group of studies was the breadth of clinical options for thalidomide with reasonable tolerability. Oral combinations like thalidomide plus corticosteroids and cyclophosphamide or melphalan looked most promising and combinations with interferon least promising.

Table 8 presents combinations of thalidomide used before or after SCT as part of the upfront therapy or maintenance program. There are six studies presented, of which three are in abstract form only; three are phase III. These data are still maturing; two studies only present blinded data. Overall, thalidomide can be used in the peri-transplant setting, but, one abstract from a randomized trial suggests that thalidomide used as part of the maintenance program after SCT may diminish options for salvage chemotherapy when it is needed in the future.110 Lower doses of thalidomide as part of a maintenance program are likely to be better.113

Figure 11 Summary of Thalidomide Efficacy for CR and PPR 25%

*Reports of PPR >50% can be misleading.

Table 2 Thalidomide efficacy – Studies of thalidomide alone in newly diagnosed and/or previously untreated multiple myeloma

Study ID | Thalidomide Dose Daily [Median length of followup] | No. of patients, age, sex, additional MM characteristics | N | Paraprotein response | Survival/other
Phase II
Rajkumar, 2001^41^ Quality 4/5 | 200–800 mg [12 mo] | 16 60 yr (38–75) 56%M 81% IgG 13% IgA 6% light chain only Previously untreated, asymptomatic SMM or IMM | 16 | Overall response (≥25%) = 81% m protein reduction: 100% = 16% ≥50%= 38% (95% CI, 18–63%) ≥25–49%=69% Stable = 19% | [median duration of response not reached @ median 1 yr f/u]
Rajkumar, 2003^42^ Quality 3/5 | 50–800 mg [median f/u= NS] | 29 61 (40–74) 55% M Previously untreated, asymptomatic SMM (66%) or IMM (34%) Reason for dx as “Indolent MM”: Lytic lesions (n=7) Hgb < 11 g/dL (n=6) IgG 83% IgA 10% | 29 | Overall response (≥25%) = 66% m protein reduction: 100% = 29% ≥50% = 34% (95% CI, 18–54%) ≥25% = 66% (95% CI, 46–82%) Stable = 34% Median time to PR = 5 mo (2–9) | Median time to progression & median duration of response not reached. PFS 80% @ 1 yr 63% @ 2 yr KM estimated OS @ 2 yr = 96%

Abbreviations: CI = confidence intervals, dL= deciliter, dx= diagnosis, f/u= followup, hgb= hemoglobin, IMM= indolent multiple myeloma, KM= Kaplan-Meier, OS= overall survival, PFS= progression free survival, PR= partial response, SMM= smoldering multiple myeloma

Table 3 Thalidomide efficacy–studies of thalidomide alone in advanced/refractory/resistant multiple myeloma

Study ID | Thalidomide Dose Daily [Median length of followup] | No. of patients, age, sex, additional MM characteristics | N | Paraprotein response | Survival/other
Phase II
Barlogie, 2001^43^ Quality 4/6 | 200–800 mg [22 mo] | 169 40% >60 yr Gender not specified advanced refractory | 169 | Overall response (≥ 25%) = 83% m protein reduction: 100% = 2% ≥ 90% = 14% ≥50% = 30% ≥25–49% = 37% | Est. OS from KM at 12 mo = 70% Est. EFS from KM at 12 mo= 25% 2-year EFS: 20% +/- 6% 2-year OS: 48% +/- 6% Of patients achieving PPR 25%, 70% achieved that response within 2 months and 90% within 4.5 months Relationship to total dose > 42 g in 3 mo had a higher response rate 25% PPR (54% v 21%) p<0.001 and superior OS (63% v 45%) p<0.001
Corso, 2002^44^ Quality 0/5 | Not randomized Group 1 =11 pts treated w/Thal 200 mg duration 210 d (90–460); 4/21 also received Dex 20mg x2d q 2wks×4 Group 2 = 10 pts treated with CAVD (≥4 cycles) CAVD (q4–6 wks): Lomustine 80mg/m2 d1 Melphalan 5mg/m2/d d1–5 Etoposide 60mg/m2/q12 D1–5 Dex 8mg/d D1–5 [Median f/u= NS] | 21 Gender not specified Thal: 59 yr (52–67) Chemo: 61 yr (46–76) | 21 Thal 11 Chemo 10 | response (≥ 25%) = 100% m protein reduction: 100% = 9% ≥90% = NS ≥50% = 36% ≥25–49% = 55% Overall response (≥ 25%) = 66% m protein reduction: 100% = NS ≥90% = NS ≥50% = 66% ≥25–49% = NS | Group 1: Median time to response = 60 d (30–190) Group 2: Median duration of response = 9 mo (3–18)
Hattori, 2004^45^ Quality 4/5 | 200–400 mg [med f/u NS] | 44 55.9 yr (30–70) 58% M relapsed autoSCT = 39%; stage 3 = 91% IgG = 55%, BJ protein = 23% IgA = 16% IgD = >1% | 44 | Overall response (≥ 25%) = 68% m protein reduction: 100% = 0% ≥90% = NS ≥50% = 27% ≥25–49% = 41%
Hus, 2001^46^ Quality 3/6 | 200–400 mg [Median f/u= NS] | 53 63 yr (32–79) 51% M Relapsed, refractory w/ hypocellular BM w/ severe pancytopenia Median time since dx = 38 mo (6–144) Historical control = 35 relapsed or resistant MM pts treated in 3 participating centers during 1990–4 | 53 Stage II = 25% Stage III = 75% Refractory = 17% Relapsed = 83% | Overall response(≥ 25%) = 58.5% m protein reduction: 100% = 7.5% ≥90% = NS ≥75% = 13% ≥50% = 23% ≥25–49% =15% | Est. OS by KM w/Thal = 250 wk (vs. 210 wk in historical controls, p<0.001) PFS = 240 wk
Johnston, 2002^47^ Quality 3/5 | 50–500 mg Median duration of Thal = 11 mo (7–15) [Median f/u= NS] | 12 67.5 yr (34–85; 42% > 70 yr) 42% M Refractory or intolerant to at least 2 prior tx not including HDT IgG = 64% Plasma cell leukemia = 4 Median time since diag = 10.5 mo (3–48) | 12 MM = 8 PCL= 4 | Overall response (≥ 25%) = 59% m protein reduction: 100% = 0% ≥90% = 13 ≥75% = 13 ≥50% = 25 ≥25–49% = 0% <25% = 25% | Median dose for PR = 175 mg (100–300)
Juliusson, 2000^48^ Quality 1/5 | 200–800 mg [Med f/u= NS] | 23 61.1 yr (44–78) 70% M Median 44 mo (7–137) since initial diagnosis Advanced, heavily pretreated Previous SCT = 43% IgG = 61% IgA = 22% B-J protein only = 17% Non-secretory = NS | 23 | Overall response (≥ 25%) = 65% m protein reduction: 100% = NS ≥90% = NS ≥75% = NS ≥50% = 43% partial ≥25–49% = 22% minor (% PPR not specified) | Median time to PR = 31d (28–81 d) 8/16 (50%) PRs on twice daily divided dosing and 2/7 (29%) on single daily dosing (actual doses in categories = NS)
Kees, 2003^49^ Quality 2/6 | 50–400 mg Not randomized Thal only = 50% (n=12) Thal/Dex = 33% (n=8; Dex started if no response to thal alone at 6 months) Thal+ VAD= 17% (n=4) Med Thal dose = 100 mg/d [Median f/u= NS] | 24 62 yr (45–83) 50% M Relapsed (19), resistant (5) IgG = 79% IgA = 8% Light chain only = 12% Stage III = 62% | | Overall response (≥ 25%) = 50% m protein reduction: 100% =NS ≥90% = NS ≥75% = 12% ≥50% = 25% ≥25–49% = 13% inclusive ≥50% = 50% Thal only = 42% Thal/Dex = 63% VAD + Thal = 50% | 3/24 pts d/c’d Thal due to side effects 1 pt died
*Kroeger, 2004 (ASH 1646)50 Quality * | 100–300 mg Pre donor lymphocyte infusion (DLI) [Median f/u= NS] | 18 53 yr (31–64) Gender not specified Progressive or residual disease not responding to prior DLI Prior allogeneic SCT = 100% | 18 | Overall response (≥ 25%) = 67% m protein reduction: 100% = 22% ≥90% = NS ≥75% = NS ≥50% = NS ≥25–49% = 45% | 2 yr estimated OS = 100% 2 yr estimated DFS = 84% Med time to response = 108 d (36–266)
Kumar, 2003^51^ Quality 4/5 | 200–800 mg [18.7 mo; Survivors 28.5 mo (19.3–34)] | 32 67 yr (36–78) 66% M Relapsed IgG = 72% Previous SCT = 16% Median time since dx = 35.1 mo (3.1–114.9) | 32 | Overall Response (≥ 25%) = 51% m protein reduction: 100% = 0% ≥90% = NS ≥75% = NS ≥50% = 31% ≥25–49% = 22% | Median PFS-KM=15.7 mo (95% CI, 8.6–25.6 mo) Median OS-KM = 22 mo (95% CI, 10.6–35.9 mo) Median duration of response for those achieving a PR = 11.9 mo (3.7–20.3)
Neben, Moehler, Egerer et al. 2001^52^ Quality 3/6 | 100–400 mg [15 mo, 0.3–20] | 54 57 yr (34–79) 69% M Progressive MM Stage III = 87% Median prior chemo cycles = 6 (0–30) & 72% 1 HDT/PBSCT IgG 44% IgA 35% | 54 | Overall Response (≥ 25%) = 57% m protein reduction: 100% = 2% ≥90% =9% ≥75% = NS ≥50% = 26% ≥25–49% = 57% | Estimated 6 mo PFS = 73% (95% CI, 62–86%)
Rajkumar, 2000^53^ Quality 3/5 | 200–800 mg [Median f/u= NS] | 16 64 yr (48–85) 69% M Median time since dx = 32 mo Relapsed, advanced 100% Stage III 88% with 2 prior chemotherapy regimens including 25% with prior HDT/SCT | 16 | Overall Response (≥25%) = 57% m protein reduction: 100% = 0% ≥90% =NS ≥75% = NS ≥50% = 25% ≥25–49% = <1% Median duration of stability = 5 mo (2–9) | After Thal: Median OS = 5 mo Median PFS = 3 mo Median Survival since diagnosis =56 mo
Richardson, 2004^54^ Quality 3/5 | 200–600 mg, 200 mg maintenance for those with response or stable disease after week 12 [7 mo] | 30 58 yr (39–70) 63% M Relapsed after HDC & SCT Stage III = 57% IgG = 46% IgA = 27% Light chain disease = 27% Median time since dx = 4.3 yr (10 mo- 10 yr) Median number of prior tx = 5 (2–7) | 26 evaluable | Overall Response (≥ 25%) = 57% m protein reduction: 100% = 0% ≥90% =NS ≥75% = NS ≥50% = 33% ≥25–49% = 10% | PFS = 67% in 26 evaluable (95% CI, 48–86%) Median PFS = 6 mo Median OS not reached; 6-month OS estimate from KM = 83% Median duration of response = 6 mo
Schey, 2003^55^ Quality 4/5 | 100–600 mg, 200 mg maintenance Median therapy duration =6 mo (3–18) Med MTD thal = 300mg [13 mo, 1–38] | 69 62 yr (39–84) Gender not specified Relapsed or refractory, including light chain & relapsed after >3 mo SCT 36% had prior autoSCT Median time since dx = 31 mo (3–132) | 69 | Overall Response (≥ 25%) = 49% m protein reduction: 100% CR = 2% ≥90% =9% ≥75% = 9% ≥50% = 17% ≥25–49% = 22% | Discontinued Thal 12% neuropathy 4% constipation Median OS = 19 mo Median PFS = 14 mo
Singhal, 1999^35^ Quality 5/5 | 200–800 mg 86% to 400 mg 68% to 600 mg 55% to 800 mg [14.5 mo (12–16)] | 84 38% > 62 yr; 73% M Previously treated & progressive IgG 61% Duration of prior therapy > 5yrs = 21% Prior HDT = 90% Interval between last cycle of chemo and thal > 1 yr = 37% (med 14 mo) | 84 | Overall Response (≥ 25%) = 32% m protein reduction: 100% = 2% ≥90% =7% ≥75% = 7% 50%= 8% ≥25–49%= 7% | 12 mo OS = 58 +/- 5% Median EFS = 3 mo At 12 mo, 22+/- 5% event free Median TTP had not been reached 12 mo rate of progression = 44 +/- 10% Median interval between start of thal and PPR by 25% = 29d (4d – 6 mo) 78% of 25% responses were evident by 2 mo Median interval between start of thal and decrease in paraprotein by 50% = 2 mo and 75% = 3 mo 23% still receiving thal 4–15 mo after starting thal (median 13 mo) Thal discontinued after med 52d (2–286) due to lack of response in 63% of pts and due to relapse in 14%
Tosi, 2001^56^ Quality 3/5 | 100–800 mg [5 mo] | 11 54.5 yr (42–60) 64% M stage III, Relapsing after autoSCT (7/11 with >1 autoSCT) Median time to Thal since dx = 51 mo median time between SCT & start of Thal = 16 mo | 11 | Overall Response (≥ 25%) = 72% m protein reduction: 100% = NS ≥90% = NS ≥75% = NS ≥50% = 36% ≥25–49% = 36% median response duration= 5 mo | Maximal PPR at median 2 mo after initiation of thal
Tosi, 2002^57^ Quality 2/5 | 100–800 mg [9 mo] | 65 63 yr (35–78) 71%M Relapsed/refractory (1 pt with newly diagnosed MM) Stage III = 94% Median time since dx = 44 mo (0–192) Prior autoSCT=37% IgG = 75% IgA = 15% Bence Jones = 8% | 60 evaluable | Overall Response (≥ 25%) = 46.6% m protein reduction: 100% = NS ≥90% = NS ≥75% =8.3% ≥50% = 20% ≥25–49% = 18.3% Median response duration = 8 mo (2–16+) | At med f/u 9 mo PFS = 25% and OS = 92% (calculated from numbers in text)
Waage, 2004^58^ Quality 4/5 | 200–800 mg [2.4 yr] | 65 63 yr (31–78) 59% M Refractory, relapsed Median time since dx = 4.2 yr (1–16) autoSCT = 83% Stage III = 88% IgG = 66% IgA = 15% Light chain = 14% | 65 | Overall Response (≥ 25%) = 34% m protein reduction: 100% = 6% ≥90% = NS ≥75% = NS ≥50% = 14% ≥25–49% = 14% | Median OS = 12 mo Survival landmarks: 3 mo = 74% 6 mo = 66% 12 mo = 49% 24 mo = 32% 16/22 responders with some reduction in paraprotein levels by 1 week of thal; by 3 weeks all responders with paraprotein reduction (70% had reached 25% reduction) 15% received full dose thal at 800 mg; 25% reduced dose due to side effects; 26% discontinued thal Side effects leading to Thal d/c: ileus (n=3) exanthema (n=2) neuropathy (n=2) somnolence (n=2) HRQOL (measured on QLQ C-30 at baseline (n=62), 12 wks (n=38), and 24 wks (n=20)): “HRQOL scores relatively stable throughout study”, except: Pain decrease by 15 (0–100 scale) Constipation increase by 32 (0–100 scale) *20 pts completing 24 wk questionnaire were responders and had higher HRQOL at baseline
Yakoub-Agha, 2000^59^ Quality 4/5 | 100–800 mg [105 d, 44–272] | 27 62 yr (35–71) 55% M Advanced, progressed after ≥2 lines of therapy Prior autoSCT = 82% IgG = 62% IgA = 26% Light chains = 8% | 27 | Overall Response (≥ 25%) = 45% m protein reduction: 100% = NS ≥90% = NS ≥75% = 15% ≥50% = 18% ≥25–49% = 12% | Median interval between initiation of thal and 25% PPR = 30d (10–97)
Yakoub-Agha, 2002^60^ Quality 6/6 | 50–800 mg [338 d, 247–611] Median total dose of thal received in first 3 mo of therapy = 34.4g (1.6–72) Mean daily dose = 400 mg/d (27–800) | 83 64 yr (40–81) 55% M Advanced, progressed after ≥2 lines of therapy IgG = 73% IgA = 18% Light chain = 6% Prior autoSCT = 70% Median time since dx = 4.2 yr (1.7–11.4) | 83 | Overall Response (≥ 25%) = 66% m protein reduction: 100% = NS ≥90% = NS ≥75% = 13%NS ≥50% = 35% ≥25–49% = 18% | Estimated OS = 391 d (95% CI , 363–577d) Median interval from initiation of thal to 25% PPR = 39d (4–123)

Abbreviations: *= abstract, autoSCT= Autologous stem cell transplant, B-J= Bence-Jones protein, BM= bone marrow, CAVD= cyclophosphamide/doxorubicin/vincristine/Dex, CI= confidence intervals, CR= Complete Response, d/c= discontinued, Dex= dexamethasone, DLI= donor lymphocyte infusion, dx = diagnosis, EFS= event free survival, f/u= followup, HDT= high dose therapy, HRQOL= health related quality of life, KM= Kaplan-Meier, LMW= low molecular weight, Med = median, NS= not stated, OS= overall survival, PBSCT= peripheral blood stem cell transplant, PCL= plasma cell leukemia, PFS= progression free survival, PPR= paraprotein reduction, pt(s)= patient(s), QLQ C-30= Quality of Life Questionnaire Cancer 30, SCT= stem cell transplant, TTP= time to progression, VAD= vincristine/doxorubicin/Dex

Table 4 Thalidomide efficacy studies – studies of thalidomide plus dexamethasone in newly diagnosed and/or previously untreated multiple myeloma

Study ID | Thalidomide Dose Daily [Median length of followup] | No. of patients, age, sex, additional MM characteristics | N | Paraprotein response | Survival/other
Phase III
*Rajkumar, 2004 (ASH 205)61; *Rajkumar, 2004 (ASCO 6508)62 Quality * 2 reports of ongoing trial = only most recent report presented here | 200 mg Thal/Dex vs. Dex alone: Thal = 200 mg. + Dex 40 mg d1–4, 9–12, 17–20 Dex alone = same dose [median f/u= NS] | 202 65 yr (range NS) Gender= NS Newly diagnosed, untreated, symptomatic MM Other MM characteristics =NS Enrollment appears to be complete | 198 evaluable at time of report | Overall Response (≥25%) = UTD m protein reduction: 100% = NS ≥90% = NS ≥50% = Thal/Dex = 58% Dex = 42% p= 0.0164 ≥25–49% = NS | Med time to response similar in both arms = 1.1 mo Grade 3 toxicity significantly increased with Thal/dex (p<0.0001): DVT(3): Thal/Dex 18%, Dex 3% Rash(3): Thal/Dex 4%, Dex 0% Bradycardia(3): Thal/Dex 1%, Dex 0% Neuropathy(3): Thal/Dex 4%, Dex 4%
*Ludwig, 2005 (ASCO 6537)63 Quality * | 200mg Thal/Dex vs. MP (melphalan/prednisone) Thal 200 mg +Dex 40 mg d1–4, 15–18 on odd cycles & d1–4 on even cycles vs. Melphalan 2.5 mg/kg d1–4 and Prednisone 2 mg/kg d1–4 q 4–6 wks All pts got zoledronate 4 mg q mo [median f/u= NS] | 137 - Enrollment ongoing (goal n = 350) 72 yr Stage III = 58% Other pt and MM characteristics NS | 93 evaluable | Overall Thal/Dex Response = 63% 100% CR = 13% Near CR = 8% 90% = 10% 50% = 17% 25% = 15% Overall M/P response = 62% CR = 4% Near CR = 11% 90% = 11% 50% = 19% 25% = 18% | ITT RR = shorter time to response Thal/Dex = 8 wk MP = 10 wk p = 0.01 Shorter best response: Thal/Dex = 11 wk MP = 39 wk p= 0.0047 Pending data on PFS & OS Analysis per protocol, not ITT: Thal/Dex = 88% MP = 68% p= 0.05
Phase II
Alexanian, 2003^64^ Quality = 1/6 | 100–400 mg + Dex20 mg/m^2^ × 4d on d1, 9 and 17 q28 days × 3 months [median f/u= NS] | Not specified Newly diagnosed | Not specified | Overall Response(≥25%) = 85% m protein reduction: 100% CR = 15% ≥75% = 70% ≥50%= NS ≥25–49%= NS | Remission onset 0.7 mo
Rajkumar, 2002^65^ Quality 4/5 | 50–200mg + Dex 40 mg ×4d on d1, 9, 17 (odd cycles) and d1 (even cycles) Dose increase to 800 mg halted after 7 pts Cycles repeated monthly [median f/u= NS]] | 50 61 yr (33–78) 62% M Newly diagnosed IgG 66% IgA 20% Light chain only = 12% | 50 | Overall Response (≥25%) = 92% m protein reduction: 100%= NS ≥90%= NS ≥50%= 64% ≥25–49%= 28% PPR ≥50%: IgG= 62% IgA= 64% Light chain only= 60% | 62% proceeded after 4 cycles of therapy to SCT
*Rajkumar, 2005 (ASCO 6632)66 Quality * | 200mg + Dex 40 mg ×4d on d1, 9, 17 (odd cycles) and d1 (even cycles) Cycles repeated monthly [21 mos] | 24 65.5 (36–78) 58% M Newly diagnosed Not going on to SCT Stage III = 25% Other MM characteristics = NS | 24 | Overall Response (≥25%) = 54% m protein reduction: 100% = 8% ≥90% = NS ≥50% = 46% ≥25–49% = NS | Med OS= 30 mo Med PFS= 19 mo Med TTP= 21 mo
Weber, 2003^67^ Quality 3/6 | 100–600 mg 28 Thal alone – pts with asymptomatic MM 40 Thal/Dex @ 20mg/m2 ×4d on d1, 9, 17 q month Not randomized If CR, Thal/Dex d/c’d after >4 months [25 mo, 9 mo] | 68 Sex & Gender = NS Previously untreated MM | 68 Thal alone=28 Thal/Dex=40 | Overall Response(≥25%) = 36–88% m protein reduction: 100% = Thal alone = 0% Thal/Dex = 16% ≥75% = Thal alone = 36% Thal/Dex = 72% ≥50% = NS ≥25–49% = NS | Median time to remission: Thal alone = 4.2 mo Thal/Dex = 0.7 mo Median time to CR: Thal/dex = 2.3 mo (1.6–2.9) Prophylactic anticoagulants also given with Thal/Dex: Coumadin n = 24 LMW heparin n = 16 >80% received thal average daily dose = 100–200mg 21/40 treated with thal/dex proceeded to autoSCT – collection was rapid and efficient

Abbreviations: *= abstract, autoSCT= Autologous stem cell transplant, B-J= Bence-Jones protein, CR= Complete Response, CS= pulse prednisone, d/c= discontinued, EFS= event free survival, f/u= followup, ITT= intention to treat, LMW= low molecular weight, NS= not stated, MP= melphalan/prednisone, OS= overall survival, PFS= progression free survival, PPR= paraprotein reduction, pt(s)= patient(s), SCT= stem cell transplant, UTD = unable to determine; TTP= time to progression

Table 5 Thalidomide efficacy studies–studies of thalidomide plus dexamethasone in advanced/refractory/resistant multiple myeloma

Study ID | Thalidomide Dose Daily [Median length of followup] | No. of patients, age, sex, additional MM characteristics | N | Paraprotein response | Survival/other
Phase II
Alexanian, 2003^64^ Quality = 1/6 | 200–800 mg; Responders maintain Thal 100–200 mg Non-responders then added Dex 20 mg/m^2^ × 4d on d1 , 9 , 17 [med f/u=NS] | 45 58 yr 55% M relapsed, resistant | 43 | PPR 50% = 26% Non-responders (n=24) + Dex: PPR 50%= 40% Cumulative PPR 50% = 50% Overall Response (≥25%) = UTD m protein reduction: 100% = NS ≥90% = NS ≥50% = 50% ≥25–49% = NS | In responders: Median time to remission = 4 mo; Median duration of remission = about 1 yr
Alexanian, 2003^64^ Quality = 1/6 Anagnotopoulos, 2003^68^ Quality 1/6 Two papers with the same data | 200–600 mg + Dex 20 mg/m^2^ × 5d repeated every 15d; Responders maintained Thal 100–150 mg with Dex × 5d q month [med f/u= NS] | 47 48 yr (31–77) Relapsed or resistant Median time from initial therapy = 36 mo Other pt and MM characteristics NS | 47 | Overall Response (≥25%) = 54% m protein reduction: 100% = 13% ≥90% = NS ≥75% = 47% ≥50% = NS ≥25–49% = NS | Median time to remission = 2 mo Median OS = 38 mo and “significantly longer in responsive pts”
Bernardeschi, 2004^69^ Quality 2/5 | 50–400 mg +Dex 40 mg ×4d q mo | 20 65.8 yr (50–83) 55% M Refractory to prior chemo Other MM characteristics NS | | Overall Response (≥25%) = 55% m protein reduction: 100% = NS ≥90% = NS ≥50% = 55% ≥25–49% = NS Recalculated % based on table | Median OS = 37 mo
Dimopoulos, 2001^70^ Quality 3/5 | 200–400 mg + Dex 20 mg/m^2^ ×4d on d1, 9 and 17 then qmo × 4d [med f/u= NS] | 44 67 yr (38–87) 73% M Refractory, resistant Median time since initial tx = 23.3 mo (2.7–134.4) | 44 | Overall Response (≥25%) = 57% m protein reduction: 100% = NS ≥90% = NS ≥75% = 30% ≥50% = 25% ≥25–49% = 2% | Med OS= 12.6 mo Med interval between start of Thal and PPR by >50% = 1.3 mo (0.75–3.6)
Myers, 2000^71^ Myers, 2001^72^ Myers, 2002^73^ Quality 2/5 2 letters of Thal and Thal/dex and 1 follow up letter of combined group | 50–400 mg Group 1 (n= 9) Thal only @ 200–600 mg71 Group 2 (n=26, n=17 added to Group 1 (10 Thal only and 7 with 4 mg Dex slow taper added for inadequate response)73 Group 3 (n=27, addition of 1 to Group 3 not specified) – in this report a total of 17 had received Dex (dose unspecified)73 [16 mo] | 27 72 yr (51–90) 67% M Relapsed after prior chemo | 27 Thal = 10 Thal/Dex=17 Dex added if no response to Thal alone | ORR both groups (≥50%) = 63% Thal only: ORR = 37% 100% = NS >75% = 15% >50% = 22% ≥25–49% = NS Thal + Dex: ORR = 100% = NS >75% = 0 >50% = 26% ≥25–49% = NS | Median duration of response: Thal = 16 mo (3–22) Thal/Dex= 7.5 mo (3–12)
Palumbo, 2001^74^ Quality 2/5 | 100 mg + Dex 40 mg/d ×4d q mo [8 mo] | 77 65 yr Gender not specified Refractory or relapsed Median time since dx = 46 mo Stage III = 43% IgG = 60% IgA=27% | 77 | Overall Response (≥25%) = 69% m protein reduction: 100% = 3% ≥90% = NS ≥75% =18% ≥50% = 23% ≥25–49% =25% | Thal ↓ 100 to 50 mg = 4% Median time to response = 4.2 mo (0.6–10.2) Med TTP = 12 mo OS not reached and 91% of pts still alive
Palumbo, 2004^75^ Quality 6/6 | 50–100 mg +Dex 40 mg d1–4 qmo Historical controls not well matched Duration of Thal tx = 4–36 mo | 120 62 yr (range = NS) Relapsed/refractory Not randomized Compared with matched controls β2M & Durie-Salmon stage treated with conventional chemo = CC Median duration since dx: With one prior chemo line: Thal/Dex= 23 mo CC = 18 mo With ≥2 chemo lines: Thal/Dex = 60 mo CC = 55 mo | 120 with 1 chemo line Thal/Dex=62 CC = 82 after ≥2 chemo lines Thal/Dex=58 CC = 38 | After 1 line of prior chemo Thal/Dex vs. CC ORR (≥25%) = 56% vs. 43% m protein reduction: 100% = NS ≥90% = NS ≥75% = 27% vs. 19% ≥50% = 29% vs. 27% ≥25–49% = NS After >2 chemo lines Thal/Dex vs. CC ORR (≥25%) = 46% vs. 42% m protein reduction: 100% = NS ≥90% = NS ≥75% = 21% vs. 17% ≥50% = 25% vs. 25% ≥25–49% = NS | Median time to maximal response to Thal/Dex = 4 mo (0.5–21) Maximal response to Thal/Dex occurred: Within 2 mo = 33% After 3 mo= 17% After 4 mo= 14% After 6 mo= 26% After 9 mo= 11% PFS: CC = 11 mo Thal/Dex = 12 mo (p = not sig) OS: CC = 21 mo Thal/Dex = 27 mo (p= 0.05) Med f/u @ 18 mo:
*Reece, 2004 (ASH 4934)76 Quality * | 50–400 mg Med Thal dose = 150mg Thal +/− CS = Pulse Prednisone 50–100 mg q2d (N=15) or Dexamethasone (N=14) [Median duration of therapy= 7 mo (1.5–19+)] | 33 73 yr (70–88) 4 = Thal alone 29 = Thal + CS Newly diagnosed = 6% Stage III = 76% IgG = 61% IgA = 30% B-J protein = 3% | 29 | Overall Response (≥25%) = 57% m protein reduction: 100% = NS ≥90% = NS ≥75% = NS ≥50% = 42% ≥25–49% =15% | OS @ 1 yr = 80% OS @ 2 yr = 55% PFS @ 1 yr = 42% PFS @ 1 yr = 20%
Tosi, 20041^35^ Quality 4/5 | 100–400 mg Thal only = 8 pt Thal + Dex 40mg/d×4d q month = 12 pt [13 mo] | 20 65.8 yr (54–76) 75% M Stage III relapsed/refractory and renal failure (creat >130 mmol/L and creat clearance <60 ml/min) Hemodialysis = 15% Med time from dx to Thal = 34 mo (2–120) Previous autoSCT = 45% | 20 | Overall Response (≥25%) = 75% m protein reduction: 100% = NS ≥90% = NS ≥75% = NS ≥50% = 45% ≥25–49% = 30% Median response duration = 7 mo (2–24) | 80% of responders (12/15) recovered renal function creat <130 mmol/L Mean OS =7 mo At 13mo f/u 8/15 responders with disease progression

Abbreviations: *= abstract, autoSCT= Autologous stem cell transplant, B-J= Bence-Jones protein, CI= Confidence Intervals, CR= Complete Response, creat= creatinine, CS= pulse prednisone, EFS= event free survival, f/u= followup, NS= not stated, OS= overall survival, PFS= progression free survival, PPR= paraprotein reduction, pt(s)= patient(s), SCT= stem cell transplant, TTP= time to progression; UTD = unable to determine

Table 6 Thalidomide efficacy studies–studies of thalidomide plus other agents in newly diagnosed and/or previously untreated multiple myeloma

Study ID | Thalidomide Dose Daily [Median length of followup] | No. of patients, age, sex, additional MM characteristics | N | Paraprotein response | Survival/other
Phase III
*Facon, 2004 (ASH 206)78 Quality^*^ | Up to 400 mg MP vs. MPT vs. MEL100: Arm A =Standard MP (assumed – exact MP regimen not stated: melphalan 4mg/m^2^ po d1–7; prednisone 40 mg/m^2^ d1–7 q6 wk × 12), Arm B =MPT = same MP + Thal up to 400 mg Arm C = MEL100 = VAD × 2 + melphalan 100 mg/m^2^ iv × 2 (w/ cyclophosphamide 3g/m^2^ for stem cell collection) [12 mos] | 200 - Enrollment ongoing (goal N = 500) Inclusion = age 65–75 yr Actual age & gender of enrolled pts = NS | 200 | Not reported | Planned interim analysis at N = 200 for safety Shows no clear advantage or disadvantage of either MP-Thal or MEL100 over MP.
*Palumbo, 2004 (ASH 207)79 Quality^*^ | 100 mg MPT vs. MP: melphalan 4 mg/m^2^ po + prednisone 40 mg/m^2^ d1–7 q mo +/−Thalidomide 100 mg Not randomized enoxaparin prophylaxis added after trial started [15 mo] | 200 – Enrollment appears complete 72 yr (56–85) Gender not specified Newly diagnosed MM MM characteristics = NS | 102 evaluable at time of report | Overall Response (≥25%) = UTD m protein reduction: 100% = UTD ≥90% = NS ≥75% =18% ≥50% = UTD ≥25–49% =UTD After MPT: CR = 25.9% Near CR = 5.5% PR = 48.2% After MP: CR = 4.2% Near CR = 0% PR = 43.6% | EFS @ 26 mos: EFS w/MPT = 67.8 % EFS w/MP = 32.4% p<0.001 OS not reached Treatment related mortality: MPT = 5% MP = 2% Adverse events: DVT: MPT 19%, MP 2% Infections (Grade 3/4): MPT 13%,MP 2% Neurotoxicity (Grade 1/2) : MPT 36%, MP 5% Hem. toxicity (Grade 3/4) : MPT 23%, MP 28%
*Alexanian, 2004 (ASH 210)80 Quality^*^ | 100–200 mg VTD: Velcade (Bortezomib) 1.0–1.9 mg/m^2^ d1, 4, 8 & 11 Thal 100–200 mg Dex 20 mg/ m^2^ q4d d1, 9, 17 Repeat VTD q4 wk [6 mo (2–14)] | 25 63 yr (39–81) Gender not specified Previously untreated MM characteristics = NS | | Overall Response (≥25%) = UTD m protein reduction: 100% = UTD ≥90% = NS ≥75% =76% ≥50% = 84% ≥25–49% = NS | Median time to remission = 0.6 mo (0.3–1.8) Autologous blood stem cells easily collected in 12 pts who were intensified for a median 3.6 mo after initial therapy
*Chanan-Khan, Miller, McCarthy, Koryzna et al., 2004 (ASH 3463)81 Quality * | 100–200 mg VAD d1–4 qmo + Thal 100–200 mg Repeat q 4wk × 4 cycles Coumadin 1–2 mg for DVT prophylaxis [Med f/u= NS] | 16 58 yr (46–77) 50% M >Stage 1 No prior therapy Stage III = 69% | 11 evaluable | Overall Response (≥25%) = 91% m protein reduction: 100% = 3% ≥90% = NS ≥75% =64% ≥50% = NS ≥25–49% = NS
*Dimopoulos, 2004 (ASH 1482)82 Quality^*^ | 300 mg MDT: Melphalan 8 mg/ m^2^ d-4, Dexamethasone 12 mg/m^2^ d1–4, 14–18 Thal 300 mg. d1–4, 14–18 Repeated q5wk × 10 cycles [15 mo] | 43 – Enrollment ongoing (goal N = NS) 78 yr (75–85) No prior therapy Inclusion = Symptomatic MM with age ≥ 75 yr Stage III = 58% Other MM characteristics = NS | 43 | Overall Response (≥25%) = 72% m protein reduction: 100% = 10% ≥90% = NS ≥75% = NS ≥50% = 62% ≥25–49% = NS | Median time to PR = 2 mo (0-5-5.5) OS @ 15 mo median f/u = 88%
*Hassoun, 2004 (ASH 2409)83 Quality^*^ | AD/TD = Doxorubicin/Dex followed by Thal/Dex Doxorubicin = 9 mg/m^2^ d1–4, Dex = 40 mg/d, d1–4, 9–12, 17–20; Thal = 200 mg Dex as above | 38 – Enrollment ongoing (goal N = NS) 59 yr (35–82) 58% M Stage II & III symptomatic MM MM characteristics = NS | 30 | Overall Response (≥25%) = 86.6% m protein reduction: 100% = 20% ≥90% = 26.6% ≥75% = NS ≥50% = 40% ≥25–49% =25%
*Klueppelberg, 2004 (ASH 4932)84; *Klueppelberg, 2004 (ASCO 6702)85; *Klueppelberg, 2005 (ASCO 6697)86 Quality^*^ 3 reports of ongoing study with increasing enrollment; most data presented here from most recent report with highest n | 100 mg TDZ: Thal 100 mg + Dex 10–40 mg d1–4, 9–12, 17–20 for 6 mo then d1–4 qmo +zoledronate 4mg qmo [Mean time on TDZ = 12 mo; 13 pts followed for 12–24 mo] | 33 61 yr (43–82) 73% F Newly diagnosed MM HIV+ = 14% Stage III = 69% Other MM characteristics=NS | 29 evaluable | Overall Response (≥25%) = 90% m protein reduction: 100% = NS ≥90% = 28% ≥75% =% ≥50% = 34% ≥25–49% =28% Cumulative probability of ≥25% PPR = 73% (+/− 20.6%) within 10 mo | Responses were unaffected to HIV status or antiviral treatment Median time to response = 5.9 mo Age-adjusted 1-year OS = 74$
Schutt, 2005^87^ Quality 5/5 | 200–400 mg Thal-VED: Thal starting at 200 mg and increasing to 400 mg/d + vincristine 1.5 mg d1 + epirubicin 30mg/m^2^/d d1–2 + Dex 20 mg/m^2^/d d1–5 Repeated q3wk Mean # cycles = 4 (1–8) [Med f/u= NS] | 31 57 yr (32–77) 68% M Untreated MM Stage III = 91% IgG = 58% IgA = 19% B-J protein = 16% Non-secretory = 7% | 31 | Overall Response (≥25%) = 80% m protein reduction: 100% = 19% ≥90% = NS ≥75% = NS ≥50% = 61% ≥25–49% = NS | EFS @ 36mo =26% OS @ 36 mo = 62% Med EFS = 36 mo Med OS not reached at 40 mo Max response to treatment achieved by median 2.8 mo (1.4–7.2 mo) 20 were candidates for SCT and PBSC were collected In all
Zervas, 2004^88^ Quality 3/5 | 200 mg + VAD + Dex 40 mg/m^2^ × 4d on d15 of cycle 1 only VAD: VCR 2mg Liposomal doxorubicin 40 mg/m^2^ Dex 40 mg/m^2^ qdx4 [10 mo, 2–22] | 39 68 yr (43–75) 51% M Newly diagnosed with symptomatic MM, Stage III = 64% IgG = 56.5% IgA = 28% Light chain = 13% | 39 | Overall Response (≥25%) = 82% m protein reduction: 100% = 10% ≥90% = NS ≥75% = NS ≥50% = 64% ≥25–49% = 8% | EFS @ 22 mo = 55% OS @ 22 mo = 74% 6 Early deaths: 4 = disease progression 2 = neutropenic infection 38% proceeded to SCT (47% of responders)

Abbreviations: *= abstract, AD/TD= Doxorubicin/Dex + Thal/Dex, alloBMT= allogeneic bone marrow transplant, B-J= Bence Jones protein, CR= Complete Response, Dex= Dexamethasone, DVT= Deep venous thrombosis, EFS= event free survival, f/u= followup, Hem= hematologic, HIV+= Human Immunodeficiency Virus Positive, IFN= Interferon, MP= melphalan/prednisone, MPT= MP + Thal, Near CR= positive IFE only, NS= not stated, OS= overall survival, PFS= progression free survival, PPR= Paraprotein reduction, PR= partial response, pt(s) = patient(s), SCT= stem cell transplant, T= Thalidomide, TDZ = Thal/Dex/ Zoledronate, UTD= unable to determine, VAD= standard chemotherapy including Vincristine/Doxorubicin/Dexamethasone, V= Velcade (Bortezomib), VCR= Vincristine, VED= combination chemotherapy including Vincristine/Etoposide/Dex, VTD= Velcade/Thal/Dex

Table 7 Thalidomide efficacy studies–studies of Thalidomide plus other agents in advanced/refractory/resistant multiple myeloma

Study ID | Thalidomide Dose Daily [Median length of follow- up] | No. of patients, age, sex, additional MM characteristics | N | Paraprotein response | Survival/other
Phase II
*Badros, 2004 (ASH 2400)89 Quality * | 100–400 mg Oblimerson 5–7 mg/kg/d × 7d q21d. D= Dex 40 mg × 4d Thal 100–400 mg [12 mo (1.5–16.6)] | 33 60 yr (28–76) 67% M Relapsed MM Median 3 prior regimens (2–4) Other MM characteristics= NS | 30 Evaluable | Overall Response (≥25%) = 80% m protein reduction: 100% = 7% Near CR = 13% ≥75% = NS ≥50% = 40% ≥25–49% = 20% | Estimated PFS = 12 mo Estimated OS = 17.4 mo Median response duration = 13 mo
Biagi, 2001^92^ Quality 1/6 (While called “phase II” by authors, reported more as a case series of 4 patients selected on response to Thal) | 200–800 mg IFNα added @ 12 wk | 4 44.8 yr (40–50) 75%M 75% extramedullary (EM) relapse after alloBMT | 4 | All 3 with EM MM had complete resolution of EM disease (but not necessarily other systemic response) | “Extramedullary myeloma is particularly sensitive to Thalidomide”
*Bibas, 2004 (ASH 4927)90 Quality * | 100+ mg Low dose Thal 100mg up to max tol dose + Dex 40 mg+ zoledronate 4 mg [2–21 mo] | 30 (53–81 yr) 73% F refractory, relapsed IgG = 80% IgA = 17% B-J protein = 3% | 30 | Overall Response (≥25%) = 63% m protein reduction: 100% = 13% ≥75% = NS ≥50% = 50% ≥25–49% = NS | Responders with neuropathy were decreased to Thal for only 10 days/mo
*Chanan-Khan, Miller, McCarthy, DiMiceli et al. 2004 (ASH 2421)91 Quality * | 200 mg VDT: Bortezomib (V), liposomal doxorubicin(D), & low-dose Thal V= 1.3 mg/m^2^ (d1,4, 15, 18); D = 20 mg/m^2^ (d1, 15); Thal 200 mg. Repeated q 4 wks for 4–6 Cycles | 18 56 yr. (44–80) 61% F Refractory/relapsed Prior SCT = 46% 16 MM & 2 Waldenström’s Macroglobulinemia; all stage III, pretreated median 2 (1–7) other prior regimens 46% SCT | 13 evaluable | Overall Response (≥25%) = 100% m protein reduction: 100% = NS ≥75% = 38% ≥50% = 62% ≥25–49% = NS
Ciepluch, 2002^93^ Quality 1/5 | 200–400 mg + Pamidronate 90 mg q28d mean treatment duration 12.4 wk (3–36 wk) [med f/u= NS] | 13 61.5 yr (35–87) 62% M resistant w/ osteolytic lesions | 13 | Overall Response (≥25%) = 76% m protein reduction: 100% = 23% “good clinical response” inclusive ≥25–99% = 53% ≥75% = NS ≥50% = NS ≥25–49% = NS | 85% of responders responded in first 4–8 wk of treatment Osteodynia: Partial improvement = 31% Marked improvement = 23% (measurement of osteodynia and definitions of improvement not stated)
Dimopoulos, 2004^94^ Quality 3/5 | 400 mg CTD: Cyclophosphamide 150mg/ m^2^ q12h d1–5 + Thal 400 mg/d d1–5 & 14–18 + Dex 20mg/ m^2^ d1–5 & 14–18 Repeated q 4 wks × 3 [med f/u= NS] | 53 64 yr (36–86) 49% M Treatment resistant = 87% 3 prior chemo regimens = 55% Prior tx with Thal = 19% Med time from initial dx to enrollment = 26 mo (3–141) IgG = 55% IgA = 25% B-J protein = 18% Non-secretory = 2% | 53 | Overall Response (≥25%) = 94% m protein reduction: 100% = 5% ≥75% = 34 ≥50% = 55% ≥25–49% = NS | Med time to response = 1.5 mo (0.46–4.82) Pts with prior treatment with Thal less likely to respond (PPR 50%, prior Thal vs. no prior Thal = 30% vs. 67%, p=0.03) Med TTP = 8.9 mo Med TTP if achieved a PPR50%= 12 mo Med OS = 17.5 mo
Garcia-Sanz, 2004^95^ Quality 4/5 | 200–800 mg ThaCyDex: Thal 200–800 mg +cyclophosphamide 50 mg qd + pulsed Dex 40mg/d x 4 days q3 weeks Med dose thal = 600mg [med f/u= 1.5 yr] | 71 65% >65 yr 52% M Refractory/relapsed Stage III= 42% IgG= 60% IgA= 20% B-J protein = 20% | 66 evaluable | Overall Response (≥25%) = 89% m protein reduction: 100% = 2%, CR increased to 10% @ 6 mo ≥75% = ≥50% = 55% ≥25–49% = 26% | @ 2 years, EFS = 57% & OS = 66%
*Hollmig, 2004 (ASH 2399)96 Quality * | 50–100 mg VATD: Bortezomib 1.0 or 1.3mg/m^2^ d1,4, 9,11); Doxorubicin 2.5–10 mg/m^2^ d1–4 & d9–12 cont infusion; Thal 50–100 mg d 1–12; Dex 20–40 mg. d1–4, & 9–12 [Med f/u= NS] | 20 Pt and MM characteristics NS | 14 evaluable | Overall Response (≥25%) = 50% m protein reduction: 100% = 0% ≥75% = 50% ≥50% = NS ≥25–49% = NS
Kasper, 2004^97^ Quality 2/5 | Thal 100–400 mg + PegIFNα 20–50 μg | 15 60 yr (56–79) 53% F Heavily pretreated 73% with 1 cycle of HDCT (SCT not stated) 80% Stage III Myeloma sub-types not stated | 15 | Overall Response (≥25%) = 40% m protein reduction: 100% = NS ≥75% = NS ≥50% = 7% ≥25–49% = 33% | PFS 14 mo (3–14) PegIFNα had to be stopped in 46% due to adverse effects
Kropff, 2003^98^ Quality 5/5 | 100–400 mg + Dex 20mg/ m^2^ x4d on d1, 9, 17 during cycle 1 then option to reduce to q28d + hyperfractionated cyclophosphamide 300 mg/ m^2^ iv q12hrs x6 doses (median 4 cycles) [med f/u=NS] | 60 43% >60 yr 67% M Refractory or relapsed IgG = 69% IgA = 16% Light chain only = 9% | 57 evaluable | Overall Response (≥25%) = 84% m protein reduction: 100% = 4% ≥75% = NS ≥50% = 68% ≥25–49% = 12% | Median EFS = 11 mo Median OS = 19 mo 67% grade IV neut w/ ≥1 cycle (median duration 3 d) Infections: grade 3 = 17% Grade 4 = 9% Neutropenic infection = 2 deaths Thal d/c ‘d for thromboembolic event = 1 Cerebrovascular event = 3 Pt choice = 1 Not documented = 3
Mileshkin, Biagi, et al., 2003^99^ Quality 5/6 | 200–1000 mg +/− IFNα @ week 12 [18 mo (6–26)] Not randomized | 75 56 Thal alone 19 Thal + IFN 64 yr (36–83, 48% >65) 61% M Relapsed or resistant (must have had systemic combination chemotherapy, Dex alone was not acceptable) Prior chemo regimens median = 3 cycles (1–7) 27% prior HD chemo | All: 75 | Overall Response (≥25%) = 29% m protein reduction: 100% = 1% ≥75% = NS ≥50% = 28% ≥25–49% = NS 38% for those ≤ 65 yr responded 17% for those > 65 yr responded (p=0.043) | Median time to response = 12.4 wk (4–114) Median PFS by KM =5.5 mo (CI, 3.6–6.8 mo) Median OS by KM = 14.6 mo (CI, 9.7 to >26.3 mo) KM Estimated for 1-year: PFS 23 % (CI, 14–34%) OS 56% (CI, 44–67%) Median survival: ≤ 65 yr = 6.7 mo > 65 yr = 4.1 mo p=0.045
*Mileshkin, 2005 (ASCO 8233)100 Quality * | Up to 800 mg Thal + celecoxib 400mg bid EORTC QLQ-C30 QOL questionnaires administered at baseline, monthly and after therapy [20 mo] | 66 No pt or MM characteristics reported | 66 | Overall Response (≥25%) = 42% m protein reduction: 100% = NS ≥75% = NS ≥50% = NS ≥25–49% = NS | PFS @ 20 mo = 6.8 mo OS @ 20 mo = 21.4 mo Med baseline global health score GHS = 58 (range 8–100; higher is better) GHS decreased in 80% between baseline and 1^st^ score For CR+PR pts (n=28): GHS declined = 54% GHS improved = 29% GHS same = 14% PR+CR pts vs. non-responders more likely to show improvement in best on-treatment GHS: 61% vs. 27%, p=0.024
Offidani, Corvatta, Marconi, Malerba, et al. 2004 101 Quality 0/6 May include pts presented below | 100–400 mg +/− melphalan 0.20mg/kg/d × 4d q 28d Thal mean daily dose = 158mg (SEM +/− 12.6) [med f/u not stated] Not randomized | 59 69 yr Advanced MM 4 = stable 55 = active progressive 4 = new diagnosis | 59 32 Thal alone 27 Thal + Melphalan | Overall Response (≥25%) = 64% m protein reduction: 100% = NS ≥75% = 10% ≥50% = 34% ≥25–49% = 20% PPR ≥50% (inclusive) = 44% TM = 63% T alone = 37% p = 0.015 | Mean duration/pt= 320 days Mean Thal dosage /pt= 52g 100 mg = 15% 200 mg = 46% 300 mg = 10% 400 mg = 29% Thal d/c’d for AE = 27% but not dose dependent 2 yr OS = 58% Peripheral neuropathy 39%: median time to PN = 16 mo PN risk factors = median dose>150 mg (p=0.038) disease history > 3yr (p=0.099) and prior tx w/ VCR (p=0.104);
Offidani, Corvatta, Marconi, Olivieri, et al. 2004^102^ Quality 6/6 May include pts presented above | 100–600 mg +/− melphalan 0.20mg/kg/d x4d q 28d (Thal-M) [13 mo] | 50 74 yr (46–84) 40% M 27 pts recruited on study and 23 pts met same eligibility criteria and included in analysis but not consented into the study >2 previous chemo tx = 54% IgG = 82% Disease hx > 60 mo = 34% Other MM characteristics NS | 50 Thal-M = 23 Thal = 23 | Thal-Melphalan: Overall Response (≥25%) = 81 % m protein reduction: 100% = 13% ≥75% = 2% ≥50% = 44% ≥25–49% = 22% Thal: Overall Response (≥25%) = % m protein reduction: 100% = NS ≥75% = 4% ≥50% = 22% ≥25–49% = 17% TM response superior to T p=0.009 | 2 yr PFS = 57% 2-yr OS = 59% PFS: Thal-Melphalan = med not reached 2yr PFS = 61% Thal = 13.1 mo 2yr PFS = 45% p=0.0356 No difference between Thal-M and Thal for OS
*Suvannasankha, 2005 (ASCO 6591)103 Quality * | 200 mg CTP: Thal 200 mg+ Cyclophosphamide 50 mg bid x21d q 28d + Prednisone 50 mg qod [18.37 mo, 95% CI 15.18– 21.52] | 37 65 yr (49–87) Gender NS Prior HDSCT = 43% Other MM characteristics NS | 35 | Overall Response (≥25%) = 69% m protein reduction: 100% = 22% Near CR = 6% ≥75% = NS ≥50% = 41% ≥25–49% = NS | Median TTP = 13.24 mo (95% CI 9.40–20.99) Median OS = 20.4+ mo Median # treatment cycles = 7 (1–12)
*Teoh, 2004 (ASH 4915)104 Quality * | 50mg DTZ: Thal 50 mg daily + Dex 20 mg d1–4qmo +zoledronate 4mg qmo Pts treated for 3 mo [med f/u= NS] | 18 Previously treated with symptomatic MM and unable to tolerate “conventional doses of Dex and/or Thal and/or chemo | | Overall Response (≥25%) = UTD m protein reduction: 100% = 22% “Good responses” (undefined) = 61% ≥75% = NS ≥50% = NS ≥25–49% = NS | Median time to remission = 8.2 mo
*Williams, 2004 (ASH 1499)105 Quality * | 100–200 mg CTD: Cyclophosphamide 500 mg. orally d1,8 &15 Thal 100–200 Dex 40 mg d1–4, 15–18 Repeated q4 wks for 2–6 cycles [19 mo] | 62 55 yr (31–73) Gender not specified Newly diagnosed = 24% Refractory to VAD = 47% Relapsed MM = 27% IgG = 61% IgA = 27% B-J protein = 10% Non-secretory = 2% | 62 New dx = 15 VAD refractory = 29 Relapsed = 17 | Newly diagnosed Overall Response (≥25%) =100% m protein reduction: 100% = 20% ≥75% = NS ≥50% = 80% ≥25–49% = NS VAD refractory Overall Response (≥25%) = 83% m protein reduction: 100% = NS ≥75% = NS ≥50% = NS ≥25–49% = 83% Relapsed: Overall Response (≥25%) = 71% m protein reduction: 100% = NS ≥75% = NS ≥50% = 71% ≥25–49% = NS
*Zangari, Barlogie, Hollmig, et al. 2004 (ASH 1480)107 Quality * | 50–200 mg V+Thal: Bortezomib (V) 1.0–1.3 mg/ m^2^ d1,4, 8, 11) + Thal (T) 50–200 mg at increasing doses per cohort Repeated q 21 days [med f/u= NS] | 79 Age >65 = 28% Gender NS Advanced refractory MM IgA = 18% Other MM characteristics NS | 79 | V alone: Overall Response (≥25%) = 25% m protein reduction: 100% = NS Near CR = 10% ≥75% = NS ≥50% = 15% ≥25–49% = NS V+Thal: Overall Response (≥25%) = 70% m protein reduction: 100% = NS Near CR = 10% ≥75% = NS ≥50% = 20% ≥25–49% = 40% | EFS = 7 mo Median OS = 21 mo

Abbreviations: *= abstract, alloBMT= allogeneic bone marrow transplant, B-J= Bence Jones protein, CI= Confidence Intervals, CR= Complete Response, CT= consolidation therapy, CTD= cyclophosphamide/Thalidomide/Dex, d/c= discontinued, Dex= Dexamethasone, DTPACE= combination chemotherapy including Dex/Thal/Cisplatin/Doxorubicin/Cyclophosphamide/Etoposide, DTZ= Dex/Thal/zoledronate, EFS= event free survival, EORTC QLQ-C30= European Organization for Research & Treatment of Cancer Quality of Life Questionnaire Core-30, EM= extramedullary, f/u= followup, GHS= global health status, HDSCT= high dose stem cell transplant, HDT= high dose therapy, IFN= Interferon, KM= Kaplan-Meier, Near CR= positive IFE only, med= median, neut= neutropenic, NS= not stated, OS= overall survival, PegIFNα= pegylated interferon alpha, PFS= progression free survival, PN= peripheral neuropathy, PR= partial response, pt(s)= patient(s), QOL= quality of life, SCT= stem cell transplant, T= Thalidomide, TTP= time to progression, tx= treatment/therapy, UTD= unable to determine, VAD= standard chemotherapy including Vincristine/Doxorubicin/Dexamethasone, V= Velcade (Bortezomib), VCR= Vincristine

Table 8 Thalidomide efficacy–thalidomide used as part of the pre or post stem cell transplantation regimen

Study ID | Thalidomide Dose Daily [Median length of followup] | No. of patients, age, sex, additional MM characteristics | N | Paraprotein response | Survival/other
Phase III
*Attal, 2004 (ASH 535)108 | Thal dose NS HDT w/VAD then auto SCT w/ melphalan 200 mg/m^2^ If no progression at 2 mo after second ASCT, randomized to 3 arms. A = no maintenance B = pamidronate C = Thal + pamidronate [26 mo (6–50)] | 580 Inclusion <65 yr “At diagnosis” Other pt and MM characteristics NS | 580 Arm A = 195 Arm B= 190 Arm C = 195 | | Probability of PFS @ 40 mo: Arm A = 53% (95% CI = 37–65) Arm B = 52% (95% CI = 36–68) Arm C = 70% (95% CI = 42–80) p=0.007 Thal also improves EFS; p<0.01 60% enrolled in Arms A and B received Thal at relapse; OS survival similar in all 3 groups
Barlogie, 2002^109^ Quality 2/6 Thalidomide as initial phase of Total Therapy program | 400 mg 50% randomized to Thal then Intensive Induction w/VAD (Thal group) or CAD/DCEP (no Thal group) then MEL & transplant; consolidation with DECP (Thal group) or DCEP/CAD (no Thal group); maintenance IFN [27 mo] | 231 20% >65 yr old gender not specified (This is a report on the first 231 randomized of a total 450; patients were randomized to Thal 400 vs. no Thal at the beginning of the Total Therapy II program – these data do not present unblinded outcomes) | 231 | BLINDED DATA – DO NOT KNOW WHICH PATIENTS RECEIVED THAL Overall Response (≥25%) =UTD m protein reduction: @ end of induction CR + near CR = 30% after second HDT cycle CR + near CR = 66% 100% CR = 46% Near CR = 20% ≥90% = NS ≥50% = % | BLINDED DATA – DO NOT KNOW WHICH PATIENTS RECEIVED THAL Overall 3 year estimated Followup EFS = 71% OS = 77%
* Barlogie, 2004 (ASH 1483)110 Quality * Thalidomide as initial phase of Total Therapy program | Updated report from Barlogie, 2004 (ASH 1483) [Evaluated at time of treatment failure = med 23 mo from enrollment] | As of 8/4/04, 104 of 668 pts enrolled have been randomized Thal = 61 No Thal = 43 | | | Thal salvage response rate = 26% No Thal salvage response rate= 51% p=0.028 Survival from time of relapse on Total Therapy II was better for those who did not receive Thal maintenance (med 29 vs. 8 mo, p = 0.0001) Hazard ratio for OS post-relapse when Thal maintenance used = 2.6 p=0.0006
Lee, 2003^21^ Quality 4/5 | 50–400 mg within DTPACE regimen DTPACE×2 cycles then if >50% response randomized to tandem SCT with high-dose melphalan or 4 more cycles of DTPACE or if <50% SCT; maintenance with Thal 50–200mg and Dex 20mg/dx4d q 4 wks –10% required a 50% dose reduction of Thalidomide by 2^nd^ cycle of DTPACE Dex 40qd×4d Thal 400 qhs Cisplatin 10mg/m2/d×4d Doxorubicin 10mg/m2/d×4d Cyclophosphamide 400 mg/m^2^/d×4d Etoposide 40mg/m^2^/d×4d | 236 60 yr (31–84) 64% M Previously treated 63% progressive disease after chemo IgG = 56% IgA = 19% Light chain = 2% | DTPACE cycle #1: 229 DTPACE cycle #2: 229 | Overall Response (≥25%) = 73% m protein reduction: 100% = 3% Near CR = 5% ≥90% = NS ≥75% = 9% ≥50% = 53 Overall Response (≥25%) = 86% m protein reduction: 100% = 7% Near Cr = 9% ≥90% = NS ≥75% = 16% ≥50% = 54% | Extensive toxicity data – cannot determine what is due to thalidomide
Phase II
Alexanian, 2002^111^ Quality 2/5 Alexanian, 2003^64^ Quality = 1/6 Two papers with the same data | 100–300 mg + Dex20 mg/m^2^×4d on d1, 9 and 17 q28 days – started 7 mo (4–20) after intensive therapy Responders maintain Thal 100–150 mg [treatment > 3 mo; med f/u not stated] | 21 54 yr (37–61) 71% M stable, partial responders after intensive CT and SCT (consolidation therapy after SCT) | 21 | Overall Response (≥25%) = 81% m protein reduction: 100% = 19% ≥90% = 38% ≥75% = 19% ≥50% = 5%
* Sengar, 2005 (ASCO 6731)112 Quality * | 50 mg After high dose melphalan+ SCT: Randomized to maintenance Thal vs. IFN randomized (unclear if phase II or phase III) | 70 – Unclear if enrolment continuing or goal n 52 yr (26–65) 74%M Stage III = 70% Other MM characteristics NS | 17 randomized | | UNBLINDED DATA NOT PRESENTED PFS = 55% OS = 60% Median duration of maintenance = 14 mo
* Stewart, 2004 (ASH 335)113 | 200–400 mg Thalidomide/Prednisone maintenance after ASCT with Melphalan 200 mg/ m^2^: Prednisone 50 mg qod + Thal 200 vs.400 mg Randomized Phase II [36.8 mo] | 67 Pt and MM characteristics NS Numbers randomized to each arm NS | 67 | Overall Response (≥25%) =UTD m protein reduction: post-tx CR or near CR = 15% @ 1 yr CR + near CR = 38% ≥90% = NS ≥50% = NS | PFS post-ASCT = 32.3 mo OS @ 1 yr = 91% Primary endpoint = incidence of dose reduction or dropout: Thal 200 arm = 31% Thal 400 arm = 64% Allowing for dose reductions, # on each arm at 18 mo after registration: Thal 200 arm = 76% Thal 400 arm = 41% Because of excessive treatment toxicity enrollment in the 400mg dose arm was closed after completing the first phase of the planned enrollment

Abbreviations: *= abstract, ASCT= Autologous stem cell transplant, CI= Confidence Intervals, CR= Complete Response, CT= consolidation therapy, DTPACE= combination chemotherapy including Dex/Thal/Cisplatin/Doxorubicin/Cyclophosphamide/Etoposide, EFS= event free survival, HDT= high dose therapy, IFN= Interferon, Near CR= +IFE only, NS= not stated, OS= overall survival, pt(s)= patient(s), SCT= stem cell transplant, UTD= unable to determine, VAD= standard chemotherapy including Vincristine/Doxorubicin/Dexamethasone

### Part 2. Adverse Effects

Adverse effects are summarized on Tables 9 and 10. Table 9 includes studies presented in the previous efficacy analysis that also included adverse events information. Table 10 represents studies that were presented as reports of adverse events only.

Review of Table 9 highlights six main themes:

1. Using data from studies of thalidomide only, thalidomide side effects include constipation (3–11 percent grade 3 and 4), neurotoxicity predominantly evident as peripheral neuropathy (1–7 percent grade 3 or 4) and sedation (3–13 percent grade 3 or 4), cardiac insufficiency due to bradycardia (2–6 percent grade 3 or 4), leukopenia (2–31 percent grade 3 and 4), and blood clots (2–10 percent grade 3 or 4).
2. In many instances, patients with more advanced multiple myeloma have more side effects, as would be expected, but not overwhelmingly more.
3. The profile of side effects shifts when dex is combined with thal. There is less peripheral neuropathy (2 percent grade 3 or 4). There are two columns for the Weber study.67 Patients represented in the column with N=28 received thal only while those in the N=40 column received thal-dex. Sixty-eight percent of patients who received thal developed some peripheral neuropathy, as opposed to 50 percent of those who did not receive dex. A similar pattern was seen in the Weber study for decreased constipation with thal-dex (68 percent vs. 55 percent). However, with dex there was more weakness/fatigue/lethargy and edema. Thromboembolic events and skin reactions appear to increase when dex is included as well.
4. Combining thalidomide with other agents increases side effects further.
5. Side effects increase as multiple myeloma advances or the patient has been exposed to other treatments.
6. Outside of the addition of dex, adding other chemotherapeutic agents generally increases the side effect profile.

Table 10 demonstrates the growing insight around thalidomide and its side effects that is rapidly accumulating in the literature. Fahdi and colleagues demonstrated that the incidence of bradycardia was 53 percent in their population of patients receiving thalidomide.117 Thalidomide does not increase the incidence of avascular necrosis when it is combined with steroids.114 Work by Badros et al. suggests that subclinical hypothyroidism with TSH >5 is about 13 percent more common with thalidomide than with conventional chemotherapy.115 Hall et al. reviewed skin reactions associated with thal and thal-dex, documenting the risk of severe exfoliative reactions like toxic epidermal necrolysis.118 Hattori et al. verified the cytopenias seen with thalidomide and documented that the neutropenia can be ameliorated with GCSF.45 Tosi documented that the neurotoxicity rate with thalidomide was nearly the same for newly diagnosed myeloma patients and those with refractory or resistant disease.77 Tosi and colleagues also documented that the peripheral neuropathy associated with thalidomide accumulates and worsens over time.121 And finally, a growing body of work from Zangari and colleagues carefully documents that the incidence of DVT is approximately 24–36 percent higher when patients receive thalidomide, that DVTs occur approximately 6 weeks after initiation of thalidomide, they may be associated with chromosome 11 abnormalities, and they do not alter the efficacy of thalidomide.126,125,124,123,122 Zangari and colleagues also document that low dose warfarin does not mitigate the DVT risk with thalidomide, but low dose enoxaparin does decrease the risk to baseline levels.

Table 9 Adverse effects reported in efficacy studies

[table image]

Table 10 Adverse effects of thalidomide–Studies of specific adverse effects

Study ID | Thalidomide Dose Daily [Median length of followup] | No. of patients, age, sex, additional MM characteristics | N | Adverse Effects | Other
*Anaissie, 2004 (ASH 3467)114 Quality * | Thal dose not specified, randomization to receive thal or not after Dexcontaining chemo ASCT, consolidation and IFN [33 mo, 5–114] | 553 | 553 | 9% Avascular necrosis (AVN) of femoral head Among thal treated pts, prevalence similar to control group (8% vs. 10%; p=0.58) | Median time to onset of AVN of femoral head 12 mo (2–41) Risk factors: Cumulative Dex dose (p=0.0006; OR 1.028; 95% CI 1.012–1.044) per Dex 40 mg Male gender (p=0.009; OR 0.390; 95%CI 0.192–0.790) Younger age (p-0.0122; OR 0.961, 95% CI 0.934–0.991/year) FDG-PET failed to detect abnormal uptake
Badros, 2002^115^ Quality 2/5 | 200–800 mg +/− chemo [med f/u NS] | 343 174 =MM treated in prior clinical trial 169 = relapsed MM Age & gender not specified | 174 92 chemo +Thal; 82 chemo 169 Thal relapsed MM | Chemo + Thal =92 20% TSH > 5 7% TSH >10 Chemo only =82 7% TSH >5 0% TSH >10 Thal = 169 22% TSH >5 14% TSH >10 | Conclusion = subclinical hypothyroidism occurred more frequently with Thal
Bowcock, 2001^116^ Quality 0/5 | Mean dose 150 mg [5 mo] | 23 65.6 yr = avg age for thromboembolism (TE) pts Gender not specified relapsed, resistant Historical control group = 18 pts with relapsed, resistant MM who had not received thal (age, gender not specified) | 23 18 | 5 DVT 2 Cerebral TE (1 = TIAs) 1 Cerebral TE (TIAs) | Conclusion = TE more common on thal
Fahdi, 2004^117^ Quality 4/6 | Combo chemo VAD/PAC then randomized to placebo vs. Thal Induction = 400 mg Maintenance = 200 mg q other day × 1 yr then 100 mg/d [med f/u NS] | 200 50 yr +/− 3 yr Gender not stated newly diagnosed | 200 Placebo = 104 Thal = 96 | Bradycardia: Baseline = 9.1% 4–12 weeks = 8.3% Baseline = 9.4% 4–12 weeks = 38.8% Thal: Overall 53% developed bradycardia; (4.8% required pacemaker) | Bradycardia defined as 30–60 beats/min. TSH, cardiac history, diabetes, & renal function were equivalent between groups
Hall, 2003^118^ Quality 1/5 | 200–800 mg Group 1 (Indolent) & group 2 (refractory) | 40 Age & gender not specified (Thal only: Group 1 Indolent = 19 & Group 2 refractory = 31) | Group 1 = 19 Group 2 = 31 | Minor = 14 Moderate = 8 Severe (exfoliative) = 1 | Minor derm toxicity = rash that didn’t require change in thal schedule; Mod = altered in schedule or dose; Severe = discontinued drug due to rash
Hall, 2003^118^ Quality 1/5 | 200–400 mg + Dex 40 mgx4d on D1, 9, 17 on odd-numbered cycles and D1 on evennumbered cycles [med f/u NS] | Thal/Dex 37 Age & gender not specified Newly diagnosed | 37 | Minor = 5 Moderate = 8 Severe =3 Toxic necrolysis =1 Erythema multiforme = 1 Exfoliative = 1 | Onset of skin reactions from 1^st^ mo until after 4 mo after Thal begun 3 pts ↓ Thal until rash resolved 5 pts interrupted Thal due to adverse reactions; resumed at lower doses 3 stopped Thal
Hattori, 2004^45^ Quality 4/5 | 200–400 mg Dose reductions + G-CSF for neutropenia [med f/u NS] | 44 55.9 yr (30–70) 58% M relapsed refractory | 44 | | 11% d/c Thal due to grade 4 cytopenia 25% had ≥ 50% drop in neutrophils (w/ lower hgb, platelets, & BM plasma cells than in nonneut. pts) 11% = concomitant thrombocytopenia; Nadir = 3–8 wk “Dose reduction and exogenous GCSF usually ameliorated neutropenia”
*Singh, 2004 (ASCO 3142)119 Quality * | Thal dose NS [med f/u NS] | 257 235 cases reviewed from FDA representing reports from clinical practice and compared to clinical trials reports in the medical literature (n=22) Includes information about completeness of age, gender, dose, etc. in study but not reported in abstract | 166 Clinical practice reports Clinical trial reports N=69 | | Case Report Information: In comparison with reports from clinical practice settings (n=166), clinical trial reports (n = 69) had higher rates of inclusion of information on: thalidomide administration dates (77% vs. 32%), DVT/PE onset date (62% vs. 23%), no of days from thal administration to DVT/PE (52% vs. 17%), and DVT/PE treatment (76% vs. 42%) [p < .0001 for each comparison]
*Spencer, 2004 (ASCO 6655)120 Quality * | Thal 200 mg + Zoledronic acid (ZA) 4 mg IV q 28d +Prednisolone 50 mg qod As post – SCT maintenance [med f/u NS] | 83 Age & gender well-matched but specifics not included 12 mo post-ASCT non-progressive MM Randomized to zoledronic acid +/− Thal | 83 enrolled 40 ZA/Thal 43 ZA alone | Higher creatinine levels (i.e. renal dysfunction) associated with: Male gender + pre-ASCT B2M >4 mg/L (p<0.001) But not cumulative ZA dose – NS Or presence of thal - NS | No evidence of PK interaction Thal to ZA.
*Tosi, 2004 (ASH 4898)77 Quality * Likely includes pts presented in report below | n = 34 on Thal 200 + Dex 40 d1–4 even cycles & d1- 4, 9–12, 17–20 odd cycles Followed by cyclophosphamide 7 g/m2 + G-CSF; then auto PBSCT. n = 40 on Thal 200 mg + Dex 40 mg d1–4 q mo [med f/u NS] | 74 >8 mo Thal/Dex treatment 34 = newly diagnosed symptomatic MM 55 yr 52% M 40 = pretreated (14 relapsed or 26 progressive) 61 yr 68% M | 74 | Neurotoxicity Newly diagnosed = 74% Grade I = 57% Grade III = 0% Pretreated = 75% Grade II = 32.5% Grade III = 27.5% | Not related to sex, M protein isotype or daily Thal dose Grades II + III correlated to longer disease duration (“significant”)
Tosi, 2005^121^ Quality 4/6 Likely second report of the pretreated pts presented in report above | 100–400 mg Some (N NS) received dex 40mg/d x4d q4 wks Eligibility criteria = on thal for > 1 year | 40 61.5 yr (34–78) 68% M Stage III = 90% Previous SCT = 55% Previous conventional chemo = 38% IgG = 68% IgA = 17% B-J protein = 12% Non-secretory = NS | 40 | Goal = evaluation of toxicity I pts exposed to long-term thal Median tx duration = 15 mo (12–44) Sub-clinical hypothyroidism = 3% Sinus bradycardia = 6% Peripheral neuropathy = 75% Grade 1: 6 months = 35% 12 months = 15% Grade 2: 6 months = 18% 12 months = 33% Grade 3: 6 months = 0% 12 months = 28% Med time to onset of sx = 11 mo (5–13) Electrophysiologic evaluation tested in all with Grade >1 neurotoxicity revealed sensory axonal polyneuropathy = 100% | Pts with longer time from diagnosis to onset of thal with higher risk of toxicity (p=0.01) but this was not related to the prior therapies used
Zangari, 2001^122^ Quality 0/5 | 400 mg (see Total Therapy II program Barlogie, 2002109) Pts randomized to thal or not within Total Therapy II [med f/u not stated] | 100 randomized 56 (32–71) 67% M 6 with previous DVT o/w equal distribution of risk factors (doesn’t state which groups 6 previous DVT were in) DVT confirmed by Doppler ultrasound or venography | Thal = 50 No thal = 50 | | DVT = 14/50 (28%) DVT = 2/50 (4%) P=0.002 Median time from start of thal to diagnosis of DVT = 42.5d (7–93d)
Zangari, Saghafifar, et al. 2002^123^ Quality 0/6 | 400 mg (see Total Therapy II program Barlogie, 2002109) Pts randomized to thal or not within Total Therapy II [med f/u not stated] | 62 randomized 61 (33–76) 58% M 3 with previous DVT o/w equal distribution of risk factors (doesn’t state which groups 6 previous DVT were in) Incidence of APC resistance in absence of Factor V Leiden mutation 23%, 8/30 thal pts and 6/32 no thal pts DVT confirmed by Doppler ultrasound or venography | Thal = 30 No thal = 32 | | DVT = 11/30 (37%) DVT = 1/32 (1%) P=0.002 Median time from start of thal to diagnosis of DVT = 42.5d (7–93d) Pts with APC resistance on thal with highest likelihood of developing DVT (50%) and developing early DVTs (p=0.04)
Zangari, Siegel, et al. 2002^124^ Quality2/6 | 400 mg Pts enrolled in 2 different Phase III studies – Total Therapy II using DT-PACE (see Total Therapy II program Barlogie, 2002109) and study with relapsed patients after autoSCT that used DCEP-T which is the same combination of agents minus doxorubicin [med f/u NS] | 232 DT-PACE: Med age = 60 Gender not stated Serum M protein = 1.7 g/dL DCEP-T: Med age = 58 Gender not stated Serum M protein = 0.01 g/dL DVT confirmed by Doppler ultrasound or venography | DT-PACE Thal including doxorubicin = 192 DCEP-T (Thal) = 40 | | DVT = 1/40 (2.5%) DVT = 31/192 (16%) P=0.02 DT-PACE with shorter time to develop DVT (p=0.04) Pts with chromosome 11 abnormalities developed DVT more frequently than those without them (23% vs. 11%, p=0.04) In addition to doxorubicin, risk factors (RF) determined to be age >60 and chromosome 11 abnormalities Cumulative incidence of DVT on thal: No doxo, No RF 3% Doxo, No RF 12% Doxo, 1 RF 23% Doxo 2 RF 46%
*Zangari, Barlogie, Lee, et al. 2004 (ASH 4914)125 Quality * | Thal dose NS DVT in Thal regimens where bortezomib (V) is added or not added to Dex & Doxorubicin without anticoagulation (VDTPACE vs. DT-PACE) [med f/u NS] | 24 Age & gender not specified | 24 pts Received 98 cycles DTPACE 69 cycles VDTPACE | 10% DVTs in these pts 0% thromboembolic events reported in these pts Historical reports of DVT in Thal/Dex = 12–16%
Zangari, 2004^126^ Quality 6/6 | 400 mg (see Total Therapy II program Barlogie, 2002109) Pts randomized to thal or not within Total Therapy II Cohort 1 = 221 pts – no anticoagulation with n=87 randomized to thal Cohort 2 = 35 pts all on thal and received low dose warfarin Cohort 3 = 130 with pts randomized to thal (n=68) receiving enoxaparin 40mg sc daily [22 mos] | 386 Age 65 yr = 18% 62% M Prior chemotherapy = 15% IgG = NS IgA = 21% B-J protein = NS Non-secretory = NS Known risk factors for DVT similar across groups Cohorts similar except Cohort 3 with significantly more pts with high LDH >190 IU/l, >50% plasma cells in BM, and platelet count <150 × 10^9^/l | 386 Cohort 1 = 221 Thal = 87 No thal = 134 Cohort 2 = 35 (all thal) Cohort 3 = 130 Thal = 68 No thal = 62 | Cohort 1 DVT incidence: Thal = 30% No thal = 4% p = 0.0001 OR DVT = 4.3 (CI 2.09–8.65) Cohort 2: Incidence of DVT similar with and without warfarin 1 mg/d (p = 0.07) Cohort 3 DVT incidence: Thal + enoxaparin = 15% No thal = 15% p = 0.81 | All DVTs occurred within 15 months of starting thal No relationship between DVT and paraprotein response

### Part 3. Predictors

The predictors tables have been divided into four sections: Table 11 reviews reports of predictors related to the presumed mechanism(s) of action of thalidomide, Table 12 reviews reports related to patient demographic factors, Table 13 reviews reports related to known clinical diagnostic tests, and Table 14 reviews reports that are related to thalidomide dosage and response factors. Each detailed table is preceded by a summary table.

Bone marrow angiogenesis has a role in the biology of multiple myeloma,8 and the anti-angiogenic properties of thalidomide provided the initial rationale for using this drug for this disease.35 Vascular endothelial growth factor (VEGF) and basic fibroblast growth factor (bFGF) are the most potent and specific factors to be known to be involved in angiogenesis. Measurement of these appears to relate to angiogenic activity and increased microvessel density. Growth of multiple myeloma is also regulated by another pro-angiogenic cytokine network where TNF-alpha and IL-6 play a key role.128 Thalidomide has strong immunomodulatory and anti-inflammatory activity and modulates T-cell subset function and cytokine production in addition to angiogenesis.128

In Table 11, the most notable finding among the predictors potentially related to the mechanism of action of thalidomide listed is the lack of consistency among any of the positive findings. None of these are consistent predictors of thalidomide response or survival with thalidomide. The heterogeneity across this group of studies is supportive of what is known―and needs to be known―in order to better elucidate the mechanism of action of thalidomide in multiple myeloma. Of note, hepatocyte growth factor (HGF) levels are reflective of tumor burden and not an indicator of specific effect of thalidomide. It is expected to decrease with tumor response and was used as a control condition for one of the studies.129

Review of the summary tables for Tables 12 and 13 suggests that the long known prognostic factors hold up with thalidomide, including age, performance status, cytogenetic abnormalities, albumin, beta-2 microglobulin, and others.

Table 14 confirms that paraprotein response with thalidomide corresponds to multiple myeloma tumor response including bone marrow response and early response predicting later response. Also, two studies suggested that higher doses of thalidomide predicted survival.60, 134

Table 11 Predictors of disease response or survival–Tumor characteristics related to the potential mechanism of thalidomide action

Summary

Prognostic factor | Number of studies indicating significant correlation with tumor response / total number of studies indicating factor | Number of studies indicating significant correlation with survival / total number of studies indicating factor
BM Microvascular Density | Equivocal 1/1 (Singhal, 1999^35^)
Serum mucin-1 (sMUC-1) | No correlation = 1/1 (Mileshkin, Prince, et al., 2003^127^) | No correlation = 1/1 (Mileshkin, Prince, et al., 2003^127^)
Fibroblast Growth Factor (FGF) | Some correlation with response = 2/4 (Dmoszynska, 2002^128; 52^) No correlation = 2/4 (Neben, Moehler, Kraemer et al. 2001^129^; Tosi, 2002^57^)
Hepatocyte growth factor (HGF) | Correlation with response = 1/1 (Neben, Moehler, Kraemer et al. 2001^129^)
Interleukin-6 (IL-6) | Some correlation with response = 2/3 (Dmoszynska, 2002^128^; Thompson, 2003^130^) No correlation = 1/3 (Neben, Moehler, Kraemer et al. 2001^129^)
Tumor necrosis factor alpha (TNFα) | Some correlation with response = 2/3 (Dmoszynska, 2002^128^; Thompson, 2003^130^) No correlation = 1/3 (Neben, Moehler, Kraemer et al. 2001^129^)
TNFα polymorphisms at position -238 of the gene promoter | Correlation with response = 1/1 (Neben, Mytilineos, et al., 2002^131^) | Correlation with survival = 1/1 (Neben, Mytilineos, et al., 2002^131^)
TNFα polymorphisms at position -308 of the gene promoter | No correlation = 1/1 (Neben, Mytilineos, et al., 2002^131^) | No correlation = 1/1 (Neben, Mytilineos, et al., 2002^131^)
t(4;14) positive multiple myeloma | Correlation with poor response to alkylating agents = 1/1 17)132)
Vascular Endothelial Growth Factor (VEGF) | Some correlation with response = 2/4 (Dmoszynska, 2002^128^; Tosi, 2002^57^) No correlation = 2/4 (Neben, Moehler, Egerer et al. 2001^52^; Neben, Moehler, Kraemer et al. 2001^129^)

Detailed review of studies

Prognostic factor | Studies indicating an association and quality | Strength of association with tumor response | Strength of association with survival
BM Microvascular Density | Singhal, 1999^35^ 84 pts with 14.5 mo med f/u Thal only Relapse/refractory [Quality 5/5] | Microvascular density and BM % of plasma cells correlated (p0.01) Although the microvascular density decreased markedly in some pts with a CR or near CR, estimates of the slope of change were not significantly different from zero among those with a response (p=0.39) or without a response (p=0.22)
Serum mucin-1 (sMUC-1) | Mileshkin, Prince, et al., 2003^127^ 75 pts w/ med f/u 18 mo Relapsed/refractory Some pts received IFN [Quality 4/6] | At 18 mo follow up, sMUC-1 is not predictive for PFS: Normal sMUC-1 = 6.1 mo Elevated sMUC-1 = 5 mo (p=0.31) | At 18 mo follow up, sMUC-1 is not predictive for OS Normal sMUC-1 = 15 mo Elevated sMUC-1 = 16 mo (p=0.31)
Fibroblast Growth Factor (FGF) | Dmoszynska, 2002^128^ 30 pts with med f/u not stated Thal alone 200–500mg Advanced, resistant [Quality 3/5] | All Pre-treatment FGF 52.9 +/− 9.6 After 8 weeks FGF 49.0 +/− 8.7 (p<0.05 compared to pretreatment) Responders = 60% Pre-treatment FGF 53.6 +/− 10.5 After 8 weeks FGF 47.0 +/− 9.0 (p<0.05 compared to pretreatment) Non-responders = 40% Pre-treatment FGF 51.9 +/− 8.6 After 8 weeks FGF 52.0 +/− 7.7 Major; 50% = 33% FGF 56.0 at pre-treatment Minor; 25% = 27% FGF 52.4 at pre-treatment (Greatest responses in those with highest VEGF and FGF pre-treatment)
Fibroblast Growth Factor (FGF) | Neben, Moehler, Egerer et al. 2001^52^ 54 pts w/ 15 mo med f/u Progressive 72% with prior HDCT/SCT Tx’d with Thal 100–400 mg [Quality 3/6] | Relationship to response to Thal: Effect 50–100 pg/ml (peripheral blood) OR 3.33 (1.33–8.33) Relationship to PFS: Effect 50–100 pg/ml HR 0.87 (0.59–1.27)
Fibroblast Growth Factor (FGF) | Neben, Moehler, Kraemer et al. 2001^129^ 51 pts with 6 mo f/u Progressive 69% with prior HDCT/SCT Tx’d with Thal 100–400 mg [Quality 3/6] | By two-sided Page test, no difference in FGF 6-mo trends between MM pts with response to Thal vs. those who did not
Fibroblast Growth Factor (FGF) | Tosi, 2002^57^ 65 pts (60 evaluable) w/ 9 mo med f/u (VEGF evaluated in 24 pts) Advanced relapse/refractory 36% with prior HDCT/SCT Tx’d with Thal 100–800mg [Quality 2/5] | FGF secretion by BM plasma cells: Thal response = (N = NS) No Thal response = (N = NS) (p = not significant)
Hepatocyte growth factor (HGF) | Neben, Moehler, Kraemer et al. 2001^129^ 51 pts with 6 mo f/u Progressive 69% with prior HDCT/SCT Tx’d with Thal 100–400 mg [Quality 3/6] | By two-sided Page test, significant difference in HGF 6- mo trends between MM pts with response to Thal vs. those who did not (p=0.02) (HGF –HGF levels are reflective of tumor burden and not an indicator of specific effect of Thal on cytokine levels)
Interleukin-6 (IL-6) | Dmoszynska, 2002^128^ 30pts with med f/u not stated Thal alone 200–500 mg Advanced, resistant [Quality 3/5] | All Pre-treatment IL-6 2.97 +/− 0.47 After 8 weeks IL-6 2.74 +/− 1.06 (p<0.05 compared to pretreatment) Responders = 60% Pre-treatment IL-6a 3.00 +/− 0.53 After 8 weeks IL-6 1.95 +/− 0.28 (p<0.001 compared to pretreatment) (p<0.001 compared to nonresponders) Non-responders = 40% Pre-treatment IL-6 2.92 +/− 0.38 After 8 weeks IL-6 3.92 +/− 0.57
Interleukin-6 (IL-6) | Neben, Moehler, Kraemer et al. 2001^129^ 51 pts with 6 mo f/u Progressive 69% with prior HDCT/SCT Tx’d with Thal 100–400 mg [Quality 3/6] | By two-sided Page test, no difference in IL6 6-mo trends between MM pts with response to Thal vs. those who did not
Interleukin-6 (IL-6) | Thompson, 2003^130^ 38 pts w/ unstated f/u Newly diagnosed (N=20) or SMM (N=18) Thal dose/duration not stated Newly diagnosed pts also received Dex at unstated dose [Quality 1/5] | Before Thal values= 3 pg/mL (0.5–24) After Thal values= 4 pg/mL (0.5–33) (p = not significant) IL-6 > 2 pg/ml (high) = poorer PFS 24% vs. 70% @ 2 year, p = 0.01
Tumor necrosis factor alpha (TNFα) | Dmoszynska, 2002^128^ 30pts with median f/u = NS Thal alone 200–500mg Advanced, resistant [Quality 3/5] | All Pre-treatment TNF-alpha 6.2 +/− 0.14 After 8 weeks TNF-alpha 6.16 +/− 0.18 Responders = 60% Pre-treatment TNF-alpha 6.2 +/− 0.16 After 8 weeks TNF-alpha 6.05 +/− 0.12 (p<0.001 compared to pretreatment) (p<0.001 compared to nonresponders) Non-responders = 40% Pre-treatment TNF-alpha 6.19 +/− 0.12 After 8 weeks TNF-alpha 6.33 +/− 0.11
Tumor necrosis factor alpha (TNFα) | Neben, Moehler, Kraemer et al. 2001^129^ 51 pts with 6 mo f/u Progressive 69% with prior HDCT/SCT Tx’d with Thal 100–400 mg [Quality 3/6] | By two-sided Page test, no difference in TNF-alpha 6-mo trends between MM pts with response to Thal vs. those who did not
Tumor necrosis factor alpha (TNFα) | Thompson, 2003^130^ 38 pts w/ f/u = NS Newly diagnosed (N=20) or SMM (N=18) Thal dose/duration = NS Newly Dex at unstated dose [Quality 1/5] | Before Thal values 11 pg/mL (10–32) After Thal values 11 pg/mL (9–19) (p = not significant) TNFα > 11 pg/ml (high) = poorer PFS 48% vs. 74% @ 2 year (p = 0.01)
TNFα polymorphisms at position -238 of the gene promoter | Neben, Mytilineos, et al., 2002^131^ 81 pts w/ 15 mo median f/u (presumed from previous study to which this design is referred52, but that study had 54 pts and this one has 81) Progressive Tx’d with Thal 100–400 mg [Quality 3/6] (presumed from52) | Peripheral blood TNFα levels: TNF -238A allele 9.7 pg/ml TNF -238G allele 5.2 pg/mL (p=0.047) PFS: TNF -238A allele 86% TNF -238G allele 44% (p=0.003) >25% reduction in M protein: TNF -238A allele 75% TNF -238G allele 38% (p=0.05) | OS: TNF -238A allele 100% TNF -238G allele 84% (p=0.07)
TNFα polymorphisms at position -308 of the gene promoter | Neben, Mytilineos, et al., 2002^131^ 81 pts w/ 15 mo median f/u (presumed from previous study to which this design is referred52, but that study had 54 pts and this one has 81) Progressive Tx’d with Thal 100–400 mg [Quality 3/6] (presumed from52) | PFS by KM: TNF -308A allele vs. TNF -308G allele (p=0.31) | OS by KM: TNF -308A allele vs. TNF -308G allele (p=0.31)
t(4;14) positive multiple myeloma | *Jaksic, 2004 (ASH 2417)132 16 pts with t(4;14) 14 received salvage Thal or Dex after relapse with alkylating agents Thal dose NS [Quality *] | Report that 64% PPR 25% with Thal and/or Dex whereas significantly shorter than expected OS with high dose alkylating agents with or without SCT – conclude that should use Thal and/or Dex based regimens for these patients
Vascular Endothelial Growth Factor (VEGF) | Dmoszynska, 2002^128^ 30pts with med f/u not stated Thal alone 200–500 mg Advanced, resistant [Quality 3/5] | All Pre-treatment VEGF 153.2 +/− 32.9 After 8 weeks VEGF 118.2 +/− 34.9 (p<0.001 compared to pretreatment) Responders = 60% Pre-treatment VEGF 154.8 +/− 36.6 After 8 weeks VEGF 106.8 +/− 29.5 (p<0.001 compared to pretreatment) (p<0.05 compared to non-responders) Non-responders = 40% Pre-treatment VEGF 150.9 +/− 27.9 After 8 weeks VEGF 135.4 +/− 36.4 Major; 50% = 33% VEGF 177.9 at pre-treatment Minor; 25% = 27% VEGF 140.9 at pre-treatment (Greatest responses in those with highest VEGF and bFGF pre-treatment)
Vascular Endothelial Growth Factor (VEGF) | Neben, Moehler, Egerer et al. 2001^52^ 54 pts w/ 15 mo median f/u Progressive 72% with prior HDCT/SCT Tx’d with Thal 100–400 mg [Quality 3/6] | Relationship to response to Thal: Effect 100–300 pg/ml (peripheral blood) OR 0.56 (0.22–1.41) Relationship to PFS: Effect 100–300 pg/ml HR 0.83 (0.47–1.46)
Vascular Endothelial Growth Factor (VEGF) | Neben, Moehler, Kraemer et al. 2001^129^ 51 pts with 6 mo f/u Progressive 69% with prior HDCT/SCT Tx’d with Thal 100–400 mg [Quality 3/6] | By two-sided Page test, no difference in VEGF 6-mo trends between MM pts with response to Thal vs. those who did not
Vascular Endothelial Growth Factor (VEGF) | Tosi, 2002 57 65 pts (60 evaluable) w/ 9 mo med f/u (VEGF evaluated in 24 pts) Advanced relapse/refractory 36% with prior HDCT/SCT Tx’d with Thal 100–800mg [Quality 2/5] | VEGF secretion by BM plasma cells: Thal response = 126.5 +/− 165 pg/ml No Thal response = 227.1 +/− 70 pg/ml (p = 0.04)

THE FOLLOWING STUDIES PRESENTED SOME NEGATIVE DATA RELEVANT TO THESE PREDICTORS (OFTEN PRESENTED IN TEXT FORM ONLY):

▪ Richardson, 2004^54^ did not find a significant association between change in IL2, IFN, sICAM-1, IL6, VEGF, or TNF-a and tumor response in a study with N=30 receiving Thal for relapse/refract MM after HDCT/SCT (results of statistical tests not reported)
▪ Thompson, 2003^130^ did not find a significant relationship between VEGF, bFGF or IL8 levels and Thal therapy, nor were any of these related to PFS (these data are in addition to IL6 and TNF findings above)
▪ Schutt, 2005^87^ also investigated IL-2R and thymidine kinase which were all significant for EFS in univariate models but not in the multivariate model (only B2M significant as on table 13); study included 31 pts with untreated MM administered Thal + vincristine + epirubicin + Dex

Abbreviations: BM = bone marrow, CR = complete response, d = day, Dex = dexamethasone, FGF = Fibroblast Growth Factor, f/u = followup, HDCT = high dose chemotherapy, HGF = Hepatocyte growth factor, HR = Hazard ratio, IFN = interferon, IL = interleukin, KM = Kaplan-Meier, med = median, mg = milligram, ml = milliliter, mo = month, NS = not stated, OR = overall response, OS = overall survival, PFS = progression free survival, pg = picogram, pt(s) = patient(s), SCT = stem cell transplant, SMM = smoldering multiple myeloma, sMUC = serum mucin, Thal = Thalidomide, TNF = tumor necrosis factor, tx’d = treated, VEGF = Vascular Endothelial Growth Factor, vs. = versus, w/= with

Table 12 Predictors of disease response or survival–Patient demographic factors that predict response to thalidomide

Summary

Prognostic factor | Number of studies indicating significant correlation with tumor response / total number of studies indicating factor | Number of studies indicating significant correlation with survival / total number of studies indicating factor
Age | Correlation with response = 2/3 (Barlogie, 2002^109^;Yakoub-Agha, 2002^60^) No correlation = 1/3 (Shaughnessy, 2003^133^) | Correlation with survival = 3/3 (Mileshkin, Biagi, et al. 2003^99^; Shaughnessy, 2003^133^; Yakoub-Agha, 2002^60^)
Gender | | Correlation with survival = 1/1 (Dimopoulos, 2004^94^)
Performance status (PS measured on the ECOG PS scale) | Correlation with response = 1/1 (Dimopoulos, 2001^70^) | Correlation with survival = 2/2 (Dimopoulos, 2001^70^; Dimopoulos, 2004^94^)
% of plasma cells in the BM | | Correlation with survival = 1/1 (Singhal, 1999^35^)
Relapsed vs. refractory disease | Correlation with response = 1/1 (Garcia-Sanz, 2004^95^)
Time from diagnosis to onset of Thal | Correlation with response = 1/1 (Yakoub-Agha, 2002^60^)

Detailed review of studies

Prognostic factor | Studies indicating an association and quality | Strength of association with tumor response | Strength of association with survival
Age | Barlogie, 2002^109^ 231 pts w/ median f/u 27 mo Newly diagnosed Thal part of Total Therapy II regimen At time of analysis, still blinded as to whether or not pts received Thal [Quality 4/6] | <65yr: CR or near CR = 70% >65 yr: CR or near CR = 53% (p=0.001)
Age | Mileshkin, Biagi, et al. 2003^99^ 75 pts w/ med f/u 18 mo Relapsed/refractory Some pts received IFN [Quality 5/6] | | <65yr: Estimated med survival = 6.7 mo >65 yr: Estimated med survival = 4.1 mo (p=0.045) HR = 1.66 (1.00–2.74)
Age | Shaughnessy, 2003^133^ 231 pts w/ median f/u 27 mo Thal within Total Therapy II regimen At time of analysis, still blinded as to whether or not pts received Thal [Quality 2/6] | EFS with age 65 yrs: HR not significant | OS with age 65 yrs: HR 2.0 (p=0.015)
Age | Yakoub-Agha, 2002^60^ 83 pts w/med f/u 338 d Thal alone Relapsed/refractory Quality 6/6 | EFS with age > 60 yrs: RR 4.08 (1.52–10.97) (p=0.005) | OS with age > 60 yrs: RR 3.46 (1.28–9.32) (p=0.014)
Gender | Dimopoulos, 2004^94^ 53 pts with med f/u NS CTD regimen = cyclophosphamide + Thal + dex Relapsed/refractory Quality 3/5 | | In multivariate analysis, gender associated with OS: Female: OS = 10.9 mo Male: OS not reached Univariate p=0.008 Multivariate p =0.009
Performance status (PS measured on the ECOG PS scale) | Dimopoulos, 2001^70^ Thal + Dex; resistant/refractory 44 pts w/ med f/u = NS [Quality 3/5] | PS= 0: Response to Thal = 83% PS >0: Response to Thal = 37% (p=0.002) | PS 0: Med survival = 13.0 mo PS >0: Med survival = 6.6 mo (p=0.002)
Performance status (PS measured on the ECOG PS scale) | Dimopoulos, 2004^94^ 53 pts with med f/u NS CTD regimen = cyclophosphamide + Thal + dex Relapsed/refractory [Quality 3/5] | | In multivariate analysis, PS associated with OS: PS 0: OS not reached PS 1: OS = 11.4 mo Univariate p=0.0001 Multivariate p <0.0001
% of plasma cells in the BM | Singhal, 1999^35^ 84 pts with median f/u 14.5 mo Thal only Relapse/refractory [Quality 5/5] | | High number of plasma cells in BM related to “short OS” (p=0.05)
Relapsed versus refractory disease | Garcia-Sanz, 2004^95^ 66 pt with med f/u 15 mo Thal combined with oral cyclophosphamide + dex [Quality 4/5] | Relationship between disease status before therapy and response at 6 mo: Relapse = 81% responding Refractory = 50% responding Multivariate p = 0.02
Time from diagnosis to onset of Thal | Yakoub-Agha, 2002^60^ 83 pts w/med f/u 338 d Thal alone Relapsed/refractory [Quality 6/6] | EFS with time <4.2 yrs: RR 3.62 (1.38–9.45) (p=0.008)

THE FOLLOWING STUDIES PRESENTED SOME NEGATIVE DATA RELEVANT TO THESE PREDICTORS (OFTEN PRESENTED IN TEXT FORM ONLY):

▪ Also reported in Mileshkin, Biagi et al. 2003^99^ but not significant = CRP, creatinine, calcium, plasma cells in BM, response to prior CT
▪ Yakoub-Agha 2002 60 also investigated RBC transfusion requirement, platelet count at onset of Thal, prior autoSCT, performance status, and relapse/refractory disease status as potential predictors of response to Thal – all of these not significant

Abbreviations: CR = complete response, CTD = cyclophosphamide + Thalidomide + Dexamethasone, d = day, Dex = Dexamethasone, ECOG = Eastern Cooperative Oncology Group, EFS = event free survival, f/u = followup, g = grams, HR = hazard ratio , IFN = interferon, med = median, mo = month, NS = not stated, OS = overall survival, PS = performance status, pt(s) = patient(s), RR = relative risk , SCT = stem cell transplant, Thal = Thalidomide, w/ = with, yr = year

Table 13 Predictors of disease response or survival–Clinical diagnostic tests that predict response to thalidomide

Summary

Prognostic factor | Number of studies indicating significant correlation with tumor response / total number of studies indicating factor | Number of studies indicating significant correlation with survival / total number of studies indicating factor
Cytogenetics | Correlation with response = 2/2 (Barlogie, 2001^43^; Shaughnessy, 2003^133^) | Correlation with survival = 1/1 (Shaughnessy, 2003^133^)
Chromosome 13 abnormality | Correlation with response = 2/3 (Barlogie, 2002^109^; Shaughnessy, 2003^133^) No correlation = 1/3 (*Attal, 2004 (ASH 535)108) | Correlation with survival = 4/4 (Barlogie, 2002^109^; Mileshkin, Biagi, et al. 2003^99^; Shaughnessy, 2003^133^; Singhal, 1999^35^)
Albumin | Some correlation with response = 2/3 (Dimopoulos, 2004^94^; Yakoub-Agha, 2002^60^) No correlation = 1/3 (Shaughnessy, 2003^133^) | Correlation with survival = 3/3 (Shaughnessy, 2003^133^; Singhal, 1999^35^; Yakoub-Agha, 2002^60^)
Beta 2 microglobulin (B2M) | Some correlation with response = 4/5 (Garcia-Sanz, 2004^95^; Shaughnessy, 2003^133^; Schutt, 2005^87; *^Attal, 2004 (ASH 535)108) No correlation = 1/5 (Neben, Moehler, Egerer et al. 2001^52^) | Correlation with survival = 3/3 (Mileshkin, Biagi, et al. 2003^99^; Shaughnessy, 2003^133^; Schutt, 2005^87^)
Hemoglobin | No correlation = 1/1 (Neben, Moehler, Egerer et al. 2001^52^) | No correlation = 2/2 (Dimopoulos, 2001^70^; Mileshkin, Biagi, et al. 2003^99^)
Platelets | Correlation with response = 1/1 (Garcia-Sanz, 2004^95^)
Serum lactose dehydrogenase (LDH) | Correlation with response = 3/3 (Dimopoulos, 2004^94^; Shaughnessy, 2003^133^; Singhal, 1999^35^) | Correlation with survival = 4/4 (Dimopoulos, 2001^70^; Dimopoulos, 2004^94^; Mileshkin, Biagi, et al. 2003^99^; Shaughnessy, 2003^133^)
C Reactive Protein (CRP) | Correlation with response = 2/2 (Shaughnessy, 2003^133^; Singhal, 1999^35^) | Correlation with survival = 1/1 (Shaughnessy, 2003^133^)
IgA isotype | Correlation with response = 1/1 (Yakoub-Agha, 2002^60^) | Correlation with survival = 1/1 (Yakoub-Agha, 2002^60^)
Light chain type | Correlation with response = 1/1 (Dimopoulos, 2001^70^) | Correlation with survival = 1/1 (Dimopoulos, 2001^70^)
Plasma cell labeling index (PCLI) | Correlation with response = 2/2 (Barlogie, 2001^43^; Singhal, 1999^35^)

Detailed review of studies

Prognostic factor | Studies indicating an association and quality | Strength of association with tumor response | Strength of association with survival
Cytogenetics | Barlogie, 2001^43^ 169 pts w/ median f/u 22 mo [Quality 4/6] | PPRs more frequent with normal cytogenetics (52% vs. 28%) (p=0.003) EFS HR: 2.15 (p<0.001) OS HR: 2.53 (p=0.002)
Cytogenetics | Shaughnessy, 2003^133^ 231 pts w/ median f/u 27 mo Thal within Total Therapy II regimen At time of analysis, still blinded as to whether or not pts received Thal [Quality 2/6] | EFS with abnormal cytogenetic findings other than chromosome 13: HR 2.1 (p=0.05) 3yr estimate of EFS: No cytogenetic abnormalities 80% Non-chromosome 13 abnormalities 66% Chromosome 13 abnormalities 39% (p<0.001) | OS with abnormal cytogenetic findings other than chromosome 13: HR not significant 3yr estimate of OS: No cytogenetic abnormalities 83% Non-chromosome 13 abnormalities 65% Chromosome 13 abnormalities 57% (p<0.001)
Chromosome 13 abnormality | Barlogie, 2002^109^ 231 pts w/ median f/u 27 mo Newly diagnosed Thal part of Total Therapy II regimen At time of analysis, still blinded as to whether or not pts received Thal [Quality 2/5] | No deletion: 3-yr EFS = 79% Deletion: 3-yr EFS = 32% (p<0.0001) | No deletion: 3-yr OS = 83% Deletion: 3-yr OS = 49% (p<0.0001)
Chromosome 13 abnormality | Mileshkin, Biagi, et al. 2003^99^ 75 pts w/ med f/u 18 mo Relapsed/refractory Some pts received IFN [Quality 2/6] | | No: HR = 1.00 Yes: HR = 3.40 (1.40–8.38)
Chromosome 13 abnormality | Shaughnessy, 2003^133^ 231 pts w/ median f/u 27 mo Thal within Total Therapy II regimen At time of analysis, still blinded as to whether or not pts received Thal [Quality 2/6] | EFS with chromosome 13 abnormality detected by cytogenetic analysis: HR 3.5 (p<0.001) EFS with chromosome 13 abnormality detected by FISH analysis: HR 3.9 (p<0.0001) 3yr estimate of EFS: No FISH chromosome 13 abnormalities 80% FISH Chromosome 13 abnormalities 62% (p=0.009) More rapid relapse for chromosome 13 abnormality: 61% vs. 38% @ 3 yr (p = 0.02) | OS with chromosome 13 abnormality detected by cytogenetic analysis: HR 3.4 (p<0.001) OS with chromosome 13 abnormality detected by FISH analysis: HR 3.4 (p=0.011) 3yr estimate of OS: No FISH chromosome 13 abnormalities 90% FISH Chromosome 13 abnormalities 65% (p=0.002) More rapid death in the setting of chromosome 13 abnormality: 43% vs. 35% @ 3 yr (p = 0.1)
Chromosome 13 abnormality | Singhal, 1999^35^ 84 pts with median f/u 14.5 mo Thal only Relapse/refractory [Quality 5/5] | | Chromosome 13 abnormality related to “short OS” (p=0.004)
Chromosome 13 abnormality | *Attal, 2004 (ASH 535)108 580 pts with med f/u 26 mo Thal as post-SCT maintenance (RCT of no maintenance pamidronate, pamidronate +Thal) [Quality *] | Deletion of chromosome 13 not associated with EFS
Albumin | Dimopoulos, 2004^94^ 53 pts with med f/u NS CTD regimen = cyclophosphamide + Thal + Dex Relapsed/refractory [Quality 3/5] | “Low albumin” significantly associated with shorter TTP Details not provided
Albumin | Shaughnessy, 2003^133^ 231 pts w/ median f/u 27 mo Thal within Total Therapy II regimen At time of analysis, still blinded as to whether or not pts received Thal [Quality 2/6] | EFS with albumin <35 g/dL: HR not significant | OS with albumin <35 g/dL: HR 1.9 (p=0.037)
Albumin | Singhal, 1999^35^ 84 pts w/ median f/u 14.5 mo Thal only Relapse/refractory [Quality 5/5] | | Low albumin related to “short OS” (p<0.001)
Albumin | Yakoub-Agha, 2002^60^ 83 pts w/med f/u 338 d Thal alone Relapsed/refractory [Quality 6/6] | EFS with albumin <30 g/l: RR 2.55 (1.05–6.17) (p=0.037) | OS with albumin <30 g/l: RR 2.85 (1.16–6.99) (p=0.022)
Beta 2 microglobulin (B2M) | Garcia-Sanz, 2004^95^ 66 pt with med f/u 15 mo Thal combined with oral cyclophosphamide + Dex [Quality 4/5] | Relationship between B2M and response at 6 mo: B2M 4 mg/l = 90% responding B2M >4 mg/l = 44% responding Multivariate p = 0.004
Beta 2 microglobulin (B2M) | Mileshkin, Biagi, et al. 2003^99^ 75 pts w/ med f/u 18 mo Relapsed/refractory Some pts received IFN [Quality 5/6] | | 3 mg/L: HR = 1.00 3–6 mg/L: HR = 2.77 (1.35–5.71) 6 mg/L: HR = 2.54 (1.23–5.23)
Beta 2 microglobulin (B2M) | Neben, Moehler, Egerer et al. 2001^52^ 54 pts w/ median f/u 15 mo Progressive 72% with prior HDCT/SCT Tx’d with Thal 100–400 mg [Quality 3/6] | Relationship to response to Thal: Effect 2.5–5.0 mg/l OR 2.16 (0.67–6.94) Relationship to PFS: Effect 2.5–5.0 mg/l HR 1.35 (0.82–2.11)
Beta 2 microglobulin (B2M) | Shaughnessy, 2003^133^ 231 pts w/ median f/u 27 mo Thal within Total Therapy II regimen At time of analysis, still blinded as to whether or not pts received Thal [Quality 2/6] | EFS with B2M 4mg/l: HR 2.0 (p=0.034) | OS with B2M 4mg/l: HR 2.3 (p=0.001)
Beta 2 microglobulin (B2M) | Schutt, 2005^87^ 31 pts with med f/u NS Thal combined with vincristine + epirubicin + Dex [Quality 5/5] | Pretreatment B2M <6 ml/L predictive of improved EFS univariate p<0.0001 multivariate p= significant but otherwise = NS | Pretreatment B2M <6 ml/L predictive of improved EFS univariate p<0.0001 multivariate p= significant but otherwise = NS
Beta 2 microglobulin (B2M) | *Attal, 2004 (ASH 535)108 580 pts with med f/u 26 mo Thal as post-SCT maintenance (RCT of no maintenance pamidronate, pamidronate + Thal) [Quality *] | Longer EFS associated with lower B2M at dx (p<0.01)
Hemoglobin | Dimopoulos, 2001^70^ Thal + Dex; resistant/refractory 44 pts w/ med f/u = NS [Quality 3/5] | | 8.5 g/dL: Med survival = 13.0 mo <8.5 g/dL: Med survival = 4.8 mo (p=0.0004)
Hemoglobin | Mileshkin, Biagi, et al. 2003^99^ 75 pts w/ med f/u 18 mo Relapsed/refractory Some pts received IFN [Quality 3/6] | | 11 g/dL: HR = 1.00 <11 g/dL: HR = 2.15 (0.70–1.89)
Hemoglobin | Neben, Moehler, Egerer et al. 2001^52^ 54 pts w/ median f/u 15 mo Progressive 72% with prior HDCT/SCT Tx’d with Thal 100–400 mg [Quality 3/6] | Relationship to response to Thal: Effect 9–12 g/dL OR 0.44 (0.10–1.93) Relationship to PFS: Effect 9–12 g/dL HR 1.19 (0.53–2.69)
Platelets | Garcia-Sanz, 2004^95^ 66 pt with med f/u 15 mo Thal combined with oral cyclophosphamide + Dex [Quality 4/5] | Relationship between platelet count and response at 6 mo: Platelet count >80 × 10^9^/lL= 78% responding Platelet count 80 × 10^9^/L = 25% responding Multivariate p = 0.004
Serum lactose dehydrogenase (LDH) | Dimopoulos, 2001^70^ Thal + Dex; resistant/refractory 44 pts w/ med f/u = NS [Quality 3/5] | | 220 IU/L: Med survival = 13.0 mo >220 IU/L: Med survival = 6.6 mo (p=0.009)
Serum lactose dehydrogenase (LDH) | Dimopoulos, 2004^94^ 53 pts with med f/u= NS CTD regimen = cyclophosphamide + Thal + Dex Relapsed/refractory [Quality 3/5] | “High levels of LDH” associated with shorter TTP High LDH: TTP = 3.7 mo Not high LDH = 11.7 mo | In multivariate analysis, LDH associated with OS: 220 IU/L: OS not reached >220 IU/L: OS = 6.6 mo Univariate p=0.003 Multivariate p <0.0001
Serum lactose dehydrogenase (LDH) | Mileshkin, Biagi, et al. 2003^99^ 75 pts w/ med f/u 18 mo Relapsed/refractory Some pts received IFN [Quality 5/6] | | ULN: HR = 1.00 >ULN: HR = 2.34 (1.32–4.17)
Serum lactose dehydrogenase (LDH) | Shaughnessy, 2003^133^ 231 pts w/ median f/u 27 mo Thal within Total Therapy II regimen At time of analysis, still blinded as to whether or not pts received Thal [Quality 2/6] | EFS with LDH 190 IU/l: HR 3.1 (p<0.001) | OS with LDH 190 IU/L: HR 1.9 (p=0.018)
Serum lactose dehydrogenase (LDH) | Singhal, 1999^35^ 84 pts with median f/u 14.5 mo Thal only Relapse/refractory [Quality 5/5] | Elevated LDH related to “brief EFS” (p=0.001)
C Reactive Protein (CRP) | Shaughnessy, 2003^133^ 231 pts w/ median f/u 27 mo Thal within Total Therapy II regimen At time of analysis, still blinded as to whether or not pts received Thal [Quality 2/6] | EFS with CRP 4.0 mg/L: HR 2.0 (p-0.041) | OS with CRP 4.0 mg/L: HR 1.8 (p=0.034)
C Reactive Protein (CRP) | Singhal, 1999^35^ 84 pts with median f/u 14.5 mo Thal only Relapse/refractory [Quality 5/5] | Elevated CRP related to “brief EFS” (p=0.007)
IgA isotype | Yakoub-Agha, 2002^60^ 83 pts w/med f/u 338 d Thal alone Relapsed/refractory [Quality 6/6] | EFS with IgA isotype: RR 3.03 (1.36–6.75) (p=0.006) | OS with IgA isotype: RR 2.2 (1.05–5.01) (p=0.039)
Light chain type | Dimopoulos, 2001^70^ Thal + Dex; resistant/refractory 44 pts w/ med f/u = NS [Quality 3/5] | Kappa: Response to Thal = 73% Lambda: Response to Thal = 25% (p=0.004) | Kappa: Med survival = 13.0 mo Lambda: Med survival = 6.6 mo (p=0.004)
Plasma cell labeling index (PCLI) | Barlogie, 2001^43^ 169 pts w/ median f/u 22 mo [Quality 4/6] | PPRs more frequent with high PCLI >0.05% (44% vs. 10%) (p<0.001) EFS HR: 1.86 (p=0.002) OS HR: 1.82 (p=0.009)
Plasma cell labeling index (PCLI) | Singhal, 1999^35^ 84 pts with median f/u 14.5 mo Thal only Relapse/refractory [Quality 5/5] | Low PCLI (assessed a continuous variable): Associated with response among group with 25% PPR (p=0.01) Associated with response among group with 50% PPR (p=0.01) Reduction in paraprotein by 25%: PCLI <0.2%: 46% PCLI >0.2%: 9% (p<0.05) Elevated PCLI related to “brief EFS” (p=0.006)

THE FOLLOWING STUDIES PRESENTED SOME NEGATIVE DATA RELEVANT TO THESE PREDICTORS (OFTEN PRESENTED IN TEXT FORM ONLY):

▪ Also reported in Mileshkin, Biagi et al. 2003^99^ but not significant = CRP, creatinine, calcium, plasma cells in BM, response to prior CT
▪ Also reported in Neben, Moehler et al. 2001^52^ but not significant = CRP, albumin
▪ According to Weber 2003^67^, no clinical or lab features including B2M and paraprotein level correlated with response to Thal
▪ Yakoub-Agha 2002 60 also investigated RBC transfusion requirement, platelet count at onset of Thal, prior autoSCT, performance status, and relapse/refractory disease status as potential predictors of response to Thal – all of these not significant
▪ Dimopoulos, 2004^94^ also investigated hemoglobin, platelet count, albumin, CRP, and BM plasma cell which were all significant for OS in univariate models but not in the multivariate model (only LDH, gender and performance status significant for predicting OS as on table, with LDH and albumin significant for predicting TTP as on table); study included 53 pts with refractory/resistant MM treated with cyclophosphamide + Thal + Dex
▪ Schutt, 2005^87^ also investigated CRP, IL-2R and thymidine kinase which were all significant for EFS in univariate models but not in the multivariate model (only B2M significant as on table); study included 31 pts with untreated MM administered Thal + vincristine + epirubicin + Dex
▪ Garcia-Sanz, 2004^95^ also investigated hemoglobin, MM isotype, and presence of extramedullary myelomatous lesions which were all significant for predicting tumor response in univariate models but not in the multivariate model (only B2M, platelets and relapse/refractory disease status significant as on table); study included 66 pts with previously treated MM administered Thal + cyclophosphamide + Dex

Abbreviations: * = abstract, BM = bone marrow, B2M = beta-2 microglobulin, FGF = Fibroblast Growth Factor , CRP = C-reactive protein, CT = chemotherapy, CTD = cyclophosphamide + Thalidomide + Dexamethasone, d = day, Dex = Dexamethasone, dL = deciliter, EFS = event free survival, FISH = fluorescence in situ hybridization , f/u = followup, g = grams, HDCT = high dose chemotherapy, HR = hazard ratio , IFN = interferon, IU = international units, L = liter, LDH = ?, med = median, mo = month, ml = milliliter, NS = not stated, OS = overall survival, PCLI = plasma cell labeling index , PPR = paraprotein reduction, pt(s) = patient(s), RCT = randomized controlled trial, RR = relative risk , SCT = stem cell transplant, Thal = Thalidomide, tx’d = treated, ULN = upper limit of normal , VEGF = Vascular endothelial growth factor, vs. = versus, w/ = with, yr = year

Table 14 Predictors of disease response or survival–Thalidomide dosage and response factors that correlate with overall response to thalidomide

Summary

Prognostic factor | Number of studies indicating significant correlation with tumor response / total number of studies indicating factor | Number of studies indicating significant correlation with survival / total number of studies indicating factor
Cumulative 3-mo Thal dosage | Some correlation with response = 1/2 (Yakoub-Agha, 2002^60^) No correlation = 1/2 (Neben, Moehler, et al. 2002^134^) | Correlation with survival = 2/2 (Neben, Moehler, et al. 2002^134^; Yakoub-Agha, 2002^60^)
Change in paraprotein levels | Correlation with response = 1/1 (Schey, 2003^55^)
Relationship between paraprotein response and BM response | Correlation with response = 1/1 (Singhal, 1999^35^)

Detailed review of studies

Prognostic factor | Studies indicating an association and quality | Strength of association with tumor response | Strength of association with survival
Cumulative 3-mo Thal dosage | Neben, Moehler, et al. 2002^134^ 83 pts w/ median f/u 17 mo Relapsed/refractory 72% with prior HDCT/SCT Tx’d with thal 100–400 mg Retrospective review [Quality 4/6] | 82% escalated to full 400 mg dose but 84% required dose reductions Thal dosage @ 400 mg @ 3 mo = 54% @ 6 mo = 33% @ 9 mo = 24% @12 mo = 17% PFS: HR for Thal total dose (interval analyzed 19.8–31.8)= 0.62 (CI 0.25–1.53) | ≥ 31.8 g Thal (400 mg qd×3 mo) = 15–20% higher predicted OS than ≤19.8 g(↓from 400 to 200 mg @1 mo) (p = 0.001) But not related to body size/weight OS: HR for Thal total dose (interval analyzed 19.8–31.8)= 0.07 (CI 0.01–0.37)
Cumulative 3-mo Thal dosage | Yakoub-Agha, 2002^60^ 83 pts w/median f/u 338 d Thal alone Relapsed/refractory [Quality 6/6] | Relationship between total dose and EFS: >34.4 g: EFS = 391 d 34.4 g: EFS = 350 d (p=0.083) Relationship between total dose and time to response: >34.4 g: TTR = 49 d 34.4 g: TTR = 88 d (p=0.009) | Relationship between total dose and OS: >34.4 g: EFS = 404 d ≤34.4 g: EFS = 363 d (p= 0.036)
Change in paraprotein levels | Schey, 2003^55^ 69 pt with median f/u 13 mo Relapsed/refractory Tx’d with Thal 50–600 [Quality 4/5] | Fall in M protein 14–28 days is correlated with M protein response at 3 mo (p<0.001) >25% fall in M protein 14–28 d after starting Thal = 25% with “improved response” at 3 mo
Relationship between paraprotein response and BM response | Singhal, 1999^35^ 84 pts with 14.5 mo median f/u (48 had BM assessments) Thal only Relapse/refractory [Quality 5/5] | Paraprotein response associated with BM response in 81%: 27/84 with paraprotein response 17/21 of those with paraprotein response on BM assessment with BM response

Abbreviations: BM = bone marrow, d = day, EFS = event free survival, f/u = followup, g = gram, HDCT = high dose chemotherapy, HR = hazard ratio , mg = milligram, mo = month, OS = overall survival, pt(s) = patient(s), RR = relative response , SCT = stem cell transplant, Thal = Thalidomide, TTR = time to response, tx’d = treated, w/= with