# Included Articles

(numbers refer to the list of articles presented in the Reference List)

First Author, Year | | Quality Table | Efficacy Table | Adverse Effects Table | Predictors Table
FULL TEXT ARTICLES
1. | Alexanian, 2002^111^ | x | x
2. | Alexanian, 2003^64^ | x | x
3. | Anagnostopoulos, 2003^68^ | x | x
4. | Badros, 2002^115^ | x | | xx
5. | Barlogie, 2001^43^ | x | x | x
6. | Barlogie, 2002^109^ | x | x | | x
7. | Bernardeschi, 2004^69^ | x | x
8. | Biagi, 2001^92^ | x | x
9. | Bowcock, 2002^116^ | x | | xx
10. | Ciepluch, 2002^93^ | x | x | x
11. | Corso, 2002^44^ | x | x
12. | Dimopoulos, 2001^70^ | x | x | x | x
13. | Dimopoulos, 2004^94^ | x | x | x | x
14. | Dmoszynska, 2002^128^ | x | | | x
15. | Fahdi, 2004^117^ | x | | xx
16. | Garcia-Sanz, 2004^95^ | x | x | | x
17. | Hall, 2003^118^ | x | | xx
18. | Hattori, 2004^45^ | x | x | xx
19. | Hus, 2001^46^ | x | x | x
20. | Johnston, 2002^47^ | x | x
21. | Juliusson, 2000^48^ | x | x
22. | Kasper, 2004^97^ | x | x
23. | Kees, 2003^49^ | x | x
24. | Kropff, 2003^98^ | x | x
25. | Kumar, 2003^51^ | x | x | x
26. | Lee, 2003^21^ | x | x
27. | Mileshkin, Biagi et al. 2003^99^ | x | x | | x
28. | Mileshkin, Prince et al. 2003^127^ | x | | | x
29. | Myers, 2000^71^ | x | x
30. | Myers, 2001^72^ | x | x
31. | Myers, 2002^73^ | x | x
32. | Neben, Moehler, Kraemer et al. 2001^129^ | x | | | x
33. | Neben, Moehler, Egerer et al. 2001^52^ | x | x | x | x
34. | Neben, Moehler et al. 2002^134^ | x | | | x
35. | Neben, Mytilineos, et al., 2002^131^ | x | | | x
36. | Offidani, Corvatta, Marconi, Malerba, et al. 2004 101 | x | x | x
37. | Offidani, Corvatta, Marconi, Olivieri, et al. 2004^102^ | x | x | x
38. | Palumbo, 2001^74^ | x | x | x
39. | Palumbo, 2004^75^ | x | x
40. | Rajkumar, 2000 53 | x | x
41. | Rajkumar, 2001 41 | x | x | x
42. | Rajkumar, 2002 65 | x | x | x
43. | Rajkumar, 2003 42 | x | x
44. | Richardson, 2004 54 | x | x | x | x
45. | Schey, 2003^55^ | x | x | x | x
46. | Schutt, 2005^87^ | x | x | x | x
47. | Shaughnessy, 2003^133^ | x | | | x
48. | Singhal, 1999^35^ | x | x | x | x
49. | Thompson, 2003^130^ | x | | | x
50. | Tosi, 2001^56^ | x | x
51. | Tosi, 2002 57 | x | x | x | x
52. | Tosi, 2004 135 | x | x
53. | Tosi, 2005^121^ | x | | xx
54. | Waage, 2004^58^ | x | x | x
55. | Weber, 2003^67^ | x | x | x | x
56. | Yakoub-Agha, 2000 59 | x | x | x
57. | Yakoub-Agha, 2002^60^ | x | x | x | x
58. | Zangari, 2001^122^ | x | | xx
59. | Zangari, Saghafifar, et al. 2002^123^ | x | | xx
60. | Zangari, Siegel, et al. 2002^124^ | x | | xx
61. | Zangari, 2004^126^ | x | | xx
62. | Zervas, 2004^88^ | x | x | x
ABSTRACT ONLY PUBLICATIONS
63. | Alexanian, 2004 (ASH 210)80 | * | x
64. | Anaissie, 2004 (ASH 3467)114 | * | | xx
65. | Attal, 2004 (ASH 535)108 | * | x | | x
66. | Badros, 2004 (ASH 2400)89 | * | x
67. | Barlogie, 2004 (ASH 1483)110 | * | x
68. | Bibas, 2004 (ASH 4927)90 | * | x
69. | Chanan-Khan, Miller, McCarthy, DiMiceli et al 2004 (ASH 2421)91 | * | x
70. | Chanan-Khan, Miller, McCarthy, Koryzna et al, 2004 (ASH 3463)81 | * | x
71. | Dimopoulos, 2004 (ASH 1482)82 | * | x
72. | Facon, 2004 (ASH 206)78 | * | x
73. | Hassoun, 2004 (ASH 2409)83 | * | x
74. | Hollmig, 2004 (ASH 2399)96 | * | x
75. | Jaksic, 2004 (ASH 2417)132 | * | | | x
76. | Klueppelberg, 2004 (ASH 4932)84 | * | x
77. | Klueppelberg, 2004 (ASCO 6702)85 | * | x
78. | Klueppelberg, 2005 (ASCO 6697)86 | * | x
79. | Kroeger, 2004 (ASH 1646)50 | * | x
80. | Ludwig, 2005 (ASCO 6537)63 | * | x
81. | Mileshkin, 2005 (ASCO 8233)100 | * | x
82. | Palumbo, 2004 (ASH 207)79 | * | x
83. | Rajkumar, 2004 (ASH 205)61 | * | x
84. | Rajkumar, 2004 (ASCO 6508)62 | * | x
85. | Rajkumar, 2005 (ASCO 6632)66 | * | x
86. | Reece, 2004 (ASH 4934)76 | * | x
87. | Sengar, 2005 (ASCO 6731)112 | * | x
88. | Singh, 2004 (ASCO 3142)119 | * | | xx
89. | Spencer, 2004 (ASCO 6655)120 | * | | xx
90. | Stewart, 2004 (ASH 335)113 | * | x
91. | Suvannasankha, 2005 (ASCO 6591)103 | * | x
92. | Teoh, 2004 (ASH 4915)104 | * | x
93. | Tosi, 2004 (ASH 4898)77 | * | | xx
94. | Williams, 2004 (ASH 1499)105 | * | x
95. | Zangari, Barlogie, Hollmig, et al. 2004 (ASH 1480)107 | * | x
96. | Zangari, Barlogie, Lee, et al. 2004 (ASH 4914)125 | * | | xx

* = abstract only, no quality score; ASH = American Society of Hematology Annual Meeting; ASCO = American Society of Clinical Oncology Annual Meeting; x = on main table; xx=on supplementary table (adverse effects only)

Alexanian R, Wang LM, Weber DM, et al. VTD (Velcade, Thalidomide, Dexamethasone) as primary therapy for newly-diagnosed multiple myeloma. Blood. 2004;104(11). Abstract #210.
Alexanian R, Weber D, Anagnostopoulos A, et al. Thalidomide with or without dexamethasone for refractory or relapsing multiple myeloma. Seminars in Hematology. 2003;40(4 Suppl 4):3-7. [pmid: 15015890].
Alexanian R, Weber D, Giralt S, et al. Consolidation therapy of multiple myeloma with thalidomide-dexamethasone after intensive chemotherapy. Annals of Oncology. 2002;13(7):1116-1119. [pmid: 12176792].
American Cancer Society. How is multiple myeloma treated?. 2005.
American Cancer Society. Cancer Facts and Figures. 2005.
Anagnostopoulos A, Weber D, Rankin K, et al. Thalidomide and dexamethasone for resistant multiple myeloma. British Journal of Haematology. 2003;121:768-771. [pmid: 12780791].
Anaissie E, Talamo G, Angtuaco E, et al. Avascular necrosis of bone after therapy for multiple myeloma: A study of 561 consecutive patients. Blood. 2004;104(11). Abstract#3467.
Anderson H, Scarffe JH, Ranson M, et al. VAD chemotherapy as remission induction for multiple myeloma. British Journal of Cancer. 1995;71(2):326-330. [pmid: 7841049].
Attal M, Harousseau JL, Leyvraz S, et al. Maintenance treatment with thalidomide after autologous transplantation for myeloma: First analysis of a prospective randomized study of the Intergroupe Francophone du Myelome (IFM 99 02). Blood. 2004;104(11). Abstract #535.
Attal M, Harousseau JL, Facon T, et al. Single versus double autologous stem-cell transplantation for multiple myeloma. New England Journal of Medicine. 2003;349(26):2495-2502. [pmid: 14695409].
Badros AZ, Goloubeva O, Ratterree B, et al. Phase II trial of oblimersen sodium (g3139), dexamethasone (dex) and thalidomide (thal) in relapsed multiple myeloma patients (pts). Blood. 2004;104(11). Abstract #2400.
Badros AZ, Siegel E, Bodenner D, et al. Hypothyroidism in patients with multiple myeloma following treatment with thalidomide. American Journal of Medicine. 2002;112(5):412-413. [pmid: 11904117].
Barlogie B, Desikan R, Eddlemon P, et al. Extended survival in advanced and refractory multiple myeloma after single-agent thalidomide: identification of prognostic factors in a phase 2 study of 169 patients. Blood. 2001;98(2):492-494. [pmid: 11435324].
Barlogie B, Rasmussen E, Tricot G, et al. Management of patients with multiple myeloma (MM) failing total therapy 2 (TT 2) according to thalidomide (THAL) randomization. Blood. 2004;104(11). Abstract #1483.
Barlogie B, Shaughnessy J. Early results of total therapy II in multiple myeloma: implications of cytogenetics and FISH. International Journal of Hematology. Suppl 1. 2002;76:337-339. [pmid: 12430877].
Barlogie B, Smith L, Alexanian R. Effective treatment of advanced multiple myeloma refractory to alkylating agents. New England Journal of Medicine. 1984;310(21):1353-1356. [pmid: 6546971].
Bernardeschi P, Dentico P, Rossi S, et al. Chemoresistant myeloma: phase II clinical study with low-dose thalidomide plus high-dose dexamethasone. Journal of Chemotherapy. Suppl 5. 2004;16:90-93. [pmid: 15675489].
Biagi JJ, Mileshkin L, Grigg AP, et al. Efficacy of thalidomide therapy for extramedullary relapse of myeloma following allogeneic transplantation. Bone Marrow Transplantation. 2001;28(12):1145-1150. [pmid: 11803357].
Bibas M, Andriani A, Viva F, et al. Intermittent low doses of thalidomide in the maintenance treatment of multiple myeloma. Blood. 2004;104(11). Abstract #4927.
Blade J, Samson D, Reece D, et al. Criteria for evaluating disease response and progression in patients with multiple myeloma treated by high-dose therapy and haemopoietic stem cell transplantation. British Journal of Haematology. 1998;102(5):1115-1123. [pmid: 9753033].
Bowcock SJ, Rassam SM, Ward SM, et al. Thromboembolism in patients on thalidomide for myeloma. Hematology. 2002;7(1):51-53. [pmid: 12171777].
Cavo M, Zamagni E, Tosi P, et al. Superiority of thalidomide and dexamethasone over vincristine-doxorubicindexamethasone (VAD) as primary therapy in preparation for autologous transplantation for multiple myeloma. Blood. 2005;106(1):35-39. [pmid: 15761019].
Cavo M, Zamagni ETP, Tacchetti P, et al. Superiority of first-line thalidomide-dexamethasone over vincristine-doxorubicin-dexamethasone in preparation for autologous stem cell transplantation for multiple myeloma. Blood. 2004;104(11). Abstract#1489.
Chanan-Khan AA, Miller KC, McCarthy P, et al. A phase II study of velcade (V), doxil (D) in combination with low-dose thalidomide (T) as salvage therapy for patients (pts) with relapsed (rel) or refractory (ref) multiple myeloma (MM) and Waldenstorm Macroglobulinemia (WM): encouraging preliminary results. Blood. 2004;104(11). Abstract #2421.
Chanan-Khan AA, Miller KC, McCarthy P, et al. VAD-t (Vincristine, adriamycin, dexamethasone and low-dose thalidomide) is an effective initial therapy with high response rates for patients with treatment naïve multiple myeloma (MM). Blood. 2004;104(11). Abstract #3463.
Ciepluch H, Baran W, Hellmann A. Combination of pamidronate and thalidomide in the therapy of treatment-resistant multiple myeloma. Medical Science Monitor. 2002;8(4):P131-P136.
Corso A, Lorenzi A, Orlandi E, et al. Advantages of using thalidomide for the management of refractory myeloma patients. Haematologica. 2002;87(3):328-328. [pmid: 11869950].
Dimopoulos MA, Anagnostopoulos A, Weber D. Treatment of plasma cell dyscrasias with thalidomide and its derivatives. Journal of Clinical Oncology. 2003;21(23):4444-4454. [pmid: 14645435].
Dimopoulos MA, Hamilos G, Zomas A, et al. Pulsed cyclophosphamide, thalidomide and dexamethasone: an oral regimen for previously treated patients with multiple myeloma. Hematology Journal. 2004;5(2):112-117. [pmid: 15048060].
Dimopoulos MA, Repoussis P, Terpos E, et al. Primary treatment with pulsed melphalan, dexamethasone, thalidomide (MDT) for symptomatic patients with multiple myeloma ≥75 years of age. Blood. 2004;104(11). Abstract #1482.
Dimopoulos MA, Zervas K, Kouvatseas G, et al. Thalidomide and dexamethasone combination for refractory multiple myeloma. Annals of Oncology. 2001;12(7):991-995. [pmid: 11521808].
Dimopoulos MA, Pouli A, Zervas K, et al. Prospective randomized comparison of vincristine, doxorubicin and dexamethasone (VAD) administered as intravenous bolus injection and VAD with liposomal doxorubicin as first-line treatment in multiple myeloma. Annals of Oncology. 2003;14(7):1039-1044. [pmid: 12853344].
Dmoszynska A, Bojarska-Junak A, Domanski D, et al. Production of proangiogenic cytokines during thalidomide treatment of multiple myeloma. Leukemia & Lymphoma. 2002;43(2):401-406. [pmid: 11999576].
Durie BG, Salmon SE. A clinical staging system for multiple myeloma. Correlation of measured myeloma cell mass with presenting clinical features, response to treatment, and survival. Cancer. 1975;36(3):842-854. [pmid: 1182674].
Durie BG, Stock-Novack, Salmon SE, et al. Prognostic value of pretreatment serum beta 2 microglobulin in myeloma: a Southwest Oncology Group Study. Blood. 1990;75(4):823-830. [pmid: 2405920].
Eriksson T, Bjorkman S, Hoglund P. Clinical pharmacology of thalidomide. European Journal of Clinical Pharmacology. 2001;57(5):365-376. [pmid: 11599654].
Facon T, Mary JY, Hulin C, et al. Randomized clinical trial comparing melphalan-prednisone (MP), mp-thalidomide (MP-THAL) and high-dose therapy using melphalan 100 mg/m2 (MEL100) for newly diagnosed myeloma patients aged 65–75 years. interim analysis of the IFM 99-06 trial on 350 patients. Blood. 2004;104(11). Abstract #206.
Fahdi IE, Gaddam V, Saucedo JF, et al. Bradycardia during therapy for multiple myeloma with thalidomide. American Journal of Cardiology. 2004;93(8):1052-1055. [pmid: 15081457].
Fonseca R, Blood E, Rue M, et al. Clinical and biologic implications of recurrent genomic aberrations in myeloma. Blood. 2003;101(11):4569-4575. [pmid: 12576322].
Garcia-Sanz R, Gonzalez-Porras JR, Hernandez JM, et al. The oral combination of thalidomide, cyclophosphamide and dexamethasone (ThaCyDex) is effective in relapsed/refractory multiple myeloma. Leukemia. 2004;18(4):856-863. [pmid: 14973508].
Greipp PR. Smoldering, asymptomatic stage 1, and indolent myeloma. Current Treatment Options in Oncology. 2000;1(2):119-126. [pmid: 12057049].
Greipp PR, San Miguel J, Durie BG, et al. International staging system for multiple myeloma. Journal of Clinical Oncology. 2005;23(15):3412-3420. [pmid: 15809451].
Grethlein S. Multiple myeloma. E-Medicine. 2004.
Hall VC, El-Azhary RA, Bouwhuis S, et al. Dermatologic side effects of thalidomide in patients with multiple myeloma. Journal of the American Academy of Dermatology. 2003;48(4):548-552. [pmid: 12664018].
Hansen OP, Clausen NA, Drivsholm A, et al. Phase III study of intermittent 5-drug regimen (VBCMP) versus intermittent 3-drug regimen (VMP) versus intermittent melphalan and prednisone (MP) in myelomatosis. Scandinavian Journal of Haematology. 1985;35(5):518-524. [pmid: 3911373].
Harousseau JL. Management of multiple myeloma. Reviews in Clinical & Experimental Hematology. 2002;6(3):253-275. [pmid: 12616698].
Hassoun H, Reich L, Klimek VM, et al. Doxorubicin and dexamethasone followed by thalidomide and dexamethasone (AD-TD) as initial therapy for symptomatic patients with multiple myeloma. Blood. 2004;104(11). Abstract #2409.
Hattori Y, Kakimoto T, Okamoto S, et al. Thalidomide-induced severe neutropenia during treatment of multiple myeloma. International Journal of Hematology. 2004;79(3):283-288. [pmid: 15168599].
He Y, Wheatley K, Clark O, et al. Early versus deferred treatment for early stage multiple myeloma. Cochrane Database of Systematic Reviews. 2005.
Hideshima T, Chauhan D, Shima Y, et al. Thalidomide and its analogs overcome drug resistance of human multiple myeloma cells to conventional therapy. Blood. 2000;96(9):2000.
Hollmig K, Stover J, Talamo G, et al. Bortezomib (Velcade™) + Adriamycin™ + Thalidomide + Dexamethasone (VATD) as an effective regimen in patients with refractory or relapsed multiple myeloma (MM). Blood. 2004;104(11). Abstract #2399.
Hus M, Dmoszynska A, Soroka-Wojtaszko M, et al. Thalidomide treatment of resistant or relapsed multiple myeloma patients. Haematologica. 2001;86(4):404-408. [pmid: 11325647].
International Myeloma Working Group. Criteria for the classification of monoclonal gammopathies, multiple myeloma and related disorders. British Journal of Haematology. 2003;121(5):749-757. [pmid: 12780789].
Jaksic WJ, Trudel S, Chang HQX, et al. t(4;14) Positive multiple myeloma is chemosensitive to dexamethasone and/or thalidomide but not alkylating agents: Rapid relapse and not primary drug resistance explains poor outcomes. Blood. 2004;104(11). Abstract #2417.
Johnston RE, Abdalla SH. Thalidomide in low doses is effective for the treatment of resistant or relapsed multiple myeloma and for plasma cell leukaemia. Leukemia & Lymphoma. 2002;43(2):351-354. [pmid: 11999568].
Juliusson G, Celsing F, Turesson I, et al. Frequent good partial remissions from thalidomide including best response ever in patients with advanced refractory and relapsed myeloma. British Journal of Haematology. 2000;109(1):89-96. [pmid: 10848786].
Kasper B, Moehler T, Neben K, et al. Combination therapy of Thalidomide and Peginterferon in patients with progressive multiple myeloma. Annals of Oncology. 2004;151:176-177. [pmid: 14679142].
Kees M, Dimou G, Sillaber C, et al. Low dose thalidomide in patients with relapsed or refractory multiple myeloma. Leukemia & Lymphoma. 2003;44(11):1943-1946. [pmid: 14738147].
Kildahl-Andersen O, Bjark P, Bondevik A, et al. Multiple myeloma in central Norway 1981–1982: a randomized clinical trial of 5-drug combination therapy versus standard therapy. Scandinavian Journal of Haematology. 1986;37(3):243-248. [pmid: 3538367].
Kildahl-Andersen O, Bjark P, Bondevik A, et al. Multiple myeloma in central and northern Norway 1981–1982: a follow-up study of a randomized clinical trial of 5-drug combination therapy versus standard therapy. European Journal of Haematology. 1998;41(1):47-51. [pmid: 3042453].
Klueppelberg U, Chen L, Aloba CM, et al. First-line, long-term treatment of multiple myeloma with thalidomide, dexamethasone, and zoledronate in combination (TDZ). Journal of Clinical Oncology. 2004;22(14S). Abstract #6702.
Klueppelberg U, Shapira I, Chen L, et al. Long-term treatment of newly-diagnosed multiple myeloma with low-dose thalidomide, dexamethasone and zoledronate (TDZ). 2005 ASCO Annual Meetings. 2005. Abstract # 6697.
Klueppelberg U, Smith E, Chen L, et al. First-line treatment of multiple myeloma with a combination of thalidomide, dexamethasone, and zoledronate (tdz) in an inner-city population with high HIV prevalence. Blood. 2004;104(11). Abstract #4932.
Kroeger N, Shimoni A, Zagrivnaja M, et al. Low dose thalidomide and donor lymphocyte infusion as adoptive immunotherapy after allogeneic stem cell transplantation in patients with multiple myeloma. Blood. 2004;104(11). Abstract #1646.
Kropff MH, Lang N, Bisping G, et al. Hyperfractionated cyclophosphamide in combination with pulsed dexamethasone and thalidomide (HyperCDT) in primary refractory or relapsed multiple myeloma. British Journal of Haematology. 2003;122(4):607-616. [pmid: 12899716].
Kumar S, Fonseca R, Dispenzieri A, et al. Bone marrow angiogenesis in multiple myeloma: effect of therapy. British Journal of Haematology. 2002;119(3):665-667. [pmid: 12437642].
Kumar S, Gertz MA, Dispenzieri A, et al. Response rate, durability of response, and survival after thalidomide therapy for relapsed multiple myeloma. Mayo Clinic Proceedings. 2003;78(1):34-39. [pmid: 12528875].
Kyle R. Dollinger M, Rosenbaum E, Cable G, editors. Multiple Myeloma. Everybody’s Guide to Cancer Therapy. 1997:592-599.
Kyle RA. Diagnosis and differential diagnosis of multiple myeloma. Up-to-Date [www.uptodate.com]. Accessed July 15, 2005.
Kyle RA. "Benign" monoclonal gammopathy―after 20 to 35 years of follow-up. Mayo Clinic Proceedings. 1993;68(1):26-36. [pmid: 8417251].
Kyle RA, Gertz MA, Witzig TE, et al. Review of 1027 patients with newly diagnosed multiple myeloma. Mayo Clinic Proceedings. 2003;78(1):21-33. [pmid: 12528874].
Kyle RA, Rajkumar SV. Multiple myeloma. New England Journal of Medicine. 2004;351(18):1860-1873. [pmid: 15509819].
Kyle RA. Clinical and laboratory manifestations of multiple myeloma. Up-to-Date [www.uptodate.com]. Accessed July 15, 2005.
Lee CK, Barlogie B, Munshi N, et al. DTPACE: an effective, novel combination chemotherapy with thalidomide for previously treated patients with myeloma. Journal of Clinical Oncology. 2003;21(14):2732-2739. [pmid: 12860952].
Lentzsch S, Rogers MS, LeBlanc R, et al. S-3-Amino-phthalimido-glutarimide inhibits angiogenesis and growth of B-cell neoplasias in mice. Cancer Research. 2002;62(8):2300-2305. [pmid: 11956087].
Ludwig H, Drach J, Tóthová E, et al. Thalidomide-Dexamethason versus Melphalan-Prednisolone as first line treatment in elderly patients with multiple myeloma: an interim analysis. 2005 ASCO Annual Meetings. 2005. Abstract #6537.
Lynch HT, Watson P, Tarantolo S, et al. Phenotypic heterogeneity in multiple myeloma families. Journal of Clinical Oncology. 1923;4(685–693).
Mileshkin L, Biagi JJ, Mitchell P, et al. Multicenter phase 2 trial of thalidomide in relapsed/refractory multiple myeloma: adverse prognostic impact of advanced age. Blood. 2003;102(1):69-77. [pmid: 12637329].
Mileshkin L, Prince HM, Seymour JF, et al. Serum MUC-1 as a marker of disease status in multiple myeloma patients receiving thalidomide. British Journal of Haematology. 2003;123(4):747-748. [pmid: 14616984].
Mileshkin LR, Roberts A, Ganju V, et al. Quality of life (QOL) assessment in patients with relapsed/refractory multiple myeloma (MM) treated with thalidomide (T) plus celecoxib (Cxb). 2005 ASCO Annual Meetings. 2005. Abstract #8233.
Mineur P, Menard JF, Le Loet X, et al. VAD or VMBCP in multiple myeloma refractory to or relapsing after cyclophosphamide-prednisone therapy (protocol MY 85). British Journal of Haematology. 1998;103(2):512-517. [pmid: 9827927].
Myeloma Trialists' Collaborative Group. Combination chemotherapy versus melphalan plus prednisone as treatment for multiple myeloma: an overview of 6,633 patients from 27 randomized trials. Journal of Clinical Oncology. 1998;16(12):3832-3842. [pmid: 9850028].
Myers B, Crouch D, Dolan G. Thalidomide treatment in advanced refreactory myeloma. British Journal of Haematology. 2000;111(3):986. [pmid: 11122165].
Myers B, Dolan G. Analysis of durability of response to thalidomide treatment for relapsed myeloma patients. British Journal of Haematology. 2002;118(1):347. [pmid: 12100175].
Myers B, Grimley C, Crouch D, et al. Lack of response to thalidomide in plasmacytomas. British Journal of Haematology. 2001;115(1):234. [pmid: 11722443].
National Cancer Institute. Multiple Myeloma and Other Plasma Cell Neoplasms (PDQ®): Treatment.
National Institute for Clinical Excellence. Gefitinib for non-small cell lung cancer - appraisal (project). London. National Institute for Clinical Excellence. 2003.
Neben K, Moehler T, Benner A, et al. Dose-dependent effect of thalidomide on overall survival in relapsed multiple myeloma. Clinical Cancer Research. 2002;8(11):3377-3382. [pmid: 12429624].
Neben k, Moehler t, Egerer g, et al. High plasma basic fibroblast growth factor concentration is associated with response to thalidomide in progressive multiple myeloma. Clinical Cancer Research. 2001;7(9):2675-2681. [pmid: 11555579].
Neben K, Moehler T, Kraemer A, et al. Response to thalidomide in progressive multiple myeloma is not mediated by inhibition of angiogenic cytokine secretion. British Journal of Haematology. 2001;115(3):605-608. [pmid: 11736942].
Neben K, Mytilineos J, Moehler TM, et al. Polymorphisms of the tumor necrosis factor-alpha gene promoter predict for outcome after thalidomide therapy in relapsed and refractory multiple myeloma. Blood. 2002;100(6):2263-2265. [pmid: 12200397].
Offidani M, Corvatta L, Marconi M, et al. Common and rare side-effects of low-dose thalidomide in multiple myeloma: focus on the dose-minimizing peripheral neuropathy. European Journal of Haematology. 2004;72(6):403-409. [pmid: 15128418].
Offidani M, Corvatta L, Marconi M, et al. Thalidomide plus oral melphalan compared with thalidomide alone for advanced multiple myeloma. Hematology Journal. 2004;5(4):312-317. [pmid: 15297847].
Oken MM, Harrington DP, Abramson N, et al. Comparison of melphalan and prednisone with vincristine, carmustine, melphalan, cyclophosphamide, and prednisone in the treatment of multiple myeloma: results of Eastern Cooperative Oncology Group Study E2479. Cancer. 1997;79(8):1561-1567. [pmid: 9118039].
Olson K, Hall T, Horton J, et al. Thalidomide (N-phthaloylglutamimide) in the treatment of advanced cancer. Clinical Pharmacological Therapy. 1965;6(292–297).
Palumbo A, Bertola A, Falco P, et al. Efficacy of low-dose thalidomide and dexamethasone as first salvage regimen in multiple myeloma. Hematology Journal. 2004;5(4):318-324. [pmid: 15297848].
Palumbo A, Bertola A, Musto P, et al. A Prospective randomized trial of oral melphalan, prednisone, thalidomide (MPT) vs. oral melphalan, prednisone (MP): An interim analysis. Blood. 2004;104(11). Abstract #207.
Palumbo A, Giaccone L, Bertola A, et al. Low-dose thalidomide plus dexamethasone is an effective salvage therapy for advanced myeloma. Haematologica. 2001;86(4):399-403. [pmid: 11325646].
Rajkumar SV, Blood E, Vesole DH, et al. Thalidomide plus dexamethasone versus dexamethasone alone in newly diagnosed multiple myeloma (E1A00): results of a phase III trial coordinated by the Eastern Cooperative Oncology Group. Blood. 2004;104(11). Abstract #205.
Rajkumar SV, Blood E, Vesole DH, et al. A randomised phase III trial of thalidomide plus dexamethasone versus dexamethasone in newly diagnosed multiple myeloma (E1A00): A trial coordinated by the Eastern Cooperative Oncology Group. Journal of Clinical Oncology. 2004;22(14S). Abstract #6508.
Rajkumar SV, Dingli D, Nowakowski G, et al. Thalidomide and Dexamethasone in newly diagnosed multiple myeloma: Long-term results in patients not undergoing upfront autologous stem cell transplantation. 2005 ASCO Annual Meetings. 2005. Abstract #6632.
Rajkumar SV, Dispenzieri A, Fonseca R, et al. Thalidomide for previously untreated indolent or smoldering multiple myeloma. Leukemia. 2001;15(8):1274-1276. [pmid: 11480571].
Rajkumar SV, Fonseca R, Dispenzieri A, et al. Thalidomide in the treatment of relapsed multiple myeloma. Mayo Clinic Proceedings. 2000;75(9):897-901. [pmid: 10994824].
Rajkumar SV, Gertz MA, Lacy MQ, et al. Thalidomide as initial therapy for early-stage myeloma. Leukemia. 2003;17(4):775-779. [pmid: 12682636].
Rajkumar SV, Hayman S, Gertz MA, et al. Combination therapy with thalidomide plus dexamethasone for newly diagnosed myeloma. Journal of Clinical Oncology. 2002;20(21):4319-4323. [pmid: 12409330].
Ramos J. Thalidomide: Price increases for cancer treatment. http://www.essentialdrugs.org/edrug/archive/200508/msg00053.php. Accessed Aug 26, 2005.
Reece DE, Chen C, Trudel S, et al. Thalidomide +/- Corticosteroids for the Treatment of Multiple Myeloma Patients ≥70 Years of Age. Blood. 2004;104(11). Abstract #4934.
Riccardi A, Mora O, Tinelli C, et al. Long-term survival of stage I multiple myeloma given chemotherapy just after diagnosis or at progression of the disease: a multicentre randomized study. Cooperative Group of Study and Treatment of Multiple Myeloma. British Journal of Cancer. 2000;82(7):1254-1260. [pmid: 10755397].
Richardson P, Anderson KC. Immunomodulatory analogs of thalidomide: an emerging new therapy in myeloma. Journal of Clinical Oncology. 2004;22(16):3212-3214. [pmid: 15249587].
Richardson P, Schlossman R, Jagannath S, et al. Thalidomide for patients with relapsed multiple myeloma after high-dose chemotherapy and stem cell transplantation: results of an open-label multicenter phase 2 study of efficacy, toxicity, and biological activity. Mayo Clinic Proceedings. 2004;79(7):875-882. [pmid: 15244383].
Samson D, Gaminara E, Newland A, et al. Infusion of vincristine and doxorubicin with oral dexamethasone as first-line therapy for multiple myeloma. Lancet. 1989;2(8668):882-885. [pmid: 2571813].
Schey SA, Cavenagh J, Johnson R, et al. An UK myeloma forum phase II study of thalidomide; long term follow-up and recommendations for treatment. Leukemia Research. 2003;27(10):909-914. [pmid: 12860011].
Schutt P, Ebeling P, Buttkereit U, et al. Thalidomide in combination with vincristine, epirubicin and dexamethasone (VED) for previously untreated patients with multiple myeloma. European Journal of Haematology. 2005;74(1):40-46. [pmid: 15613105].
Segeren CM, Sonneveld P, van der Holt B, et al. Vincristine, doxorubicin and dexamethasone (VAD) administered as rapid intravenous infusion for first-line treatment in untreated multiple myeloma. British Journal of Haematology. 1999;105(1):127-130. [pmid: 10233375].
Sengar M, Kumar L, Ganessan K, et al. Role of post transplant maintenance therapy in multiple myeloma : Results from a developing country. 2005 ASCO Annual Meetings. 2005. Abstract #6731.
Shaughnessy J, Tian E, Sawyer J, et al. Prognostic impact of cytogenetic and interphase fluorescence in situ hybridization-defined chromosome 13 deletion in multiple myeloma: early results of total therapy II. British Journal of Haematology. 2003;120(1):44-52. [pmid: 12492575].
Singh V, Klinge A, Luminari S, et al. Understanding thalidomide-associated deep vein thrombosis/pulmonary emboli (DVT/PE): Comparison of quality and information included in adverse event reports from clinical trials, clinical practice, STEPS, and the medical literature. Journal of Clinical Oncology. 2004;22(14S). Abstract #3142.
Singhal S, Mehta J, Desikan R, et al. Antitumor activity of thalidomide in refractory multiple myeloma. New England Journal of Medicine. 1999;341(21):1565-1571. [pmid: 10564685].
Spencer A, Roberts A, Neeman T, et al. Renal safety evaluation of zoledronic acid and thalidomide when used as post-stem cell transplant maintenance therapy in multiple myeloma. Journal of Clinical Oncology. 2004;22(14S). Abstract #6655.
Stewart AK, Chen C, Howson-Jan K, et al. Results of a multi-center randomized phase II trial of thalidomide and prednisone maintenance therapy for multiple myeloma following autologous stem cell transplant. Blood. 2004;104. Abstract #335.
Suvannasankha A, Fausel C, Juliar BE, et al. Final report of a phase II study of oral cyclophosphamide, thalidomide, and prednisone (CTP) for patients with relapsed or refractory multiple myeloma: a Hoosier Oncology Group Trial: HEM01-21. 2005 ASCO Annual Meetings. 2005. Abstract #6591.
Teoh G, Hwang W, Koh LP, et al. Low dose dexamethasone and thalidomide with higher frequency zoledronic acid (DTZ) for multiple myeloma. Blood. 2004;104(1). Abstract #4915.
Thompson MA, Witzig TE, Kumar S, et al. Plasma levels of tumour necrosis factor alpha and interleukin-6 predict progression-free survival following thalidomide therapy in patients with previously untreated multiple myeloma. British Journal of Haematology. 2003;123(2):305-308. [pmid: 14531913].
Tosi P, Ronconi S, Zamagni E, et al. Salvage therapy with thalidomide in multiple myeloma patients relapsing after autologous peripheral blood stem cell transplantation. Haematologica. 2001;86(4):409-413. [pmid: 11325648].
Tosi P, Zamagni E, Cellini C, et al. Thalidomide-induced peropheral neuropathy in newly diagnosed and pre-treated multiple myeloma patients. Blood. 2004;104(11). Abstract #4898.
Tosi P, Zamagni E, Cellini C, et al. Thalidomide alone or in combination with dexamethasone in patients with advanced, relapsed or refractory multiple myeloma and renal failure. European Journal of Haematology. 2004;73(2):98-103. [pmid: 15245508].
Tosi P, Zamagni E, Cellini C, et al. Neurological toxicity of long-term (>1 yr) thalidomide therapy in patients with multiple myeloma. European Journal of Haematology. 2005;74(3):212-216. [pmid: 15693790].
Tosi P, Zamagni E, Cellini C, et al. Salvage therapy with thalidomide in patients with advanced relapsed/refractory multiple myeloma. Haematologica. 2002;87(4):408-414. [pmid: 11940485].
Waage A, Gimsing P, Juliusson G, et al. Early response predicts thalidomide efficiency in patients with advanced multiple myeloma. British Journal of Haematology. 2004;125(2):149-155. [pmid: 15059136].
Weber D, Rankin K, Gavino M, et al. Thalidomide alone or with dexamethasone for previously untreated multiple myeloma. Journal of Clinical Oncology. 2003;21(1):16-19. [pmid: 12506164].
Williams CD, Byrne JL, Sidra G, et al. Combination chemotherapy with cyclophosphamide, thalidomide and dexamethasone achieves a high response rate in patients with newly diagnosed, VAD-refractory and relapsed myeloma. Blood. 2004;104(11). Abstract #1499.
Wilson JS, Connock M, Song FJ, et al. Imatinib mesylate for the treatment of patients with unresectable and/or metastatic gastrointestinal stromal tumours (GIST). Health Technology Assessment. 2003.
Yakoub-Agha I, Attal M, Dumontet C, et al. Thalidomide in patients with advanced multiple myeloma: a study of 83 patients--report of the Intergroupe Francophone du Myelome (IFM). Hematology Journal. 2002;3(4):185-192. [pmid: 12189564].
Yakoub-Agha I, Moreau P, Leyvraz S, et al. Thalidomide in patients with advanced multiple myeloma. Hematology Journal. 2000;1(3):186-189. [pmid: 11920188].
Zangari M, Anaissie E, Barlogie B, et al. Increased risk of deep-vein thrombosis in patients with multiple myeloma receiving thalidomide and chemotherapy. Blood. 2001;98(5):1614-1615. [pmid: 11520815].
Zangari M, Barlogie B, Anaissie E, et al. Deep vein thrombosis in patients with multiple myeloma treated with thalidomide and chemotherapy: effects of prophylactic and therapeutic anticoagulation. British Journal of Haematology. 2004;126(5):715-721. [pmid: 15327525].
Zangari M, Barlogie B, Hollmig K, et al. Marked Activity of Velcade Plus Thalidomide (V+T) in Advanced and Refractory Multiple Myeloma (MM). Blood. 2004;104(11). Abstract #1480.
Zangari M, Barlogie B, Lee C-K, et al. Protective Effect of VELCADE® on Thalidomide-Associated Deep Vein Thrombosis (DVT). Blood. 2004;104(11). Abstract #4914.
Zangari M, Saghafifar F, Anaissie E, et al. Activated protein C resistance in the absence of factor V Leiden mutation is a common finding in multiple myeloma and is associated with an increased risk of thrombotic complications. Blood Coagulation & Fibrinolysis. 2002;13(3):187-192. [pmid: 11943931].
Zangari M, Siegel E, Barlogie B, et al. Thrombogenic activity of doxorubicin in myeloma patients receiving thalidomide: implications for therapy. Blood. 2002;100(4):1168-1171. [pmid: 12149193].
Zervas K, Dimopoulos MA, Hatzicharissi E, et al. Primary treatment of multiple myeloma with thalidomide, vincristine, liposomal doxorubicin and dexamethasone (T-VAD doxil): a phase II multicenter study. Annals of Oncology. 2004;15(1):134-138. [pmid: 14679133].